# Appendix O. Intervention Characteristic Definitions ^1^

[underlined: Comprehensive behavioral treatment:] those using a combination of three types of interventions: behavioral modification procedures, a special diet, and an exercise program
Exercise programs; - Broad; - Specific; - [underlined: Aerobic (] e.g., running, jogging, swimming); - High intensity; - Low intensity; - [underlined: Calisthenic] (e.g., sit-ups, toe-touches); - [underlined: Lifestyle] (e.g., taking staircase, walking to store); [underlined: Decreased sedentary behavior] ^2^ (e.g., limiting watching television or video games)
Diet programs
Behavioral modification components; - [underlined: Self-monitoring:] having the child document diet-related behaviors or physical activity; - [underlined: Stimulus control:] modifying factors that appear to serve as cues leading to inappropriate eating, such as while watching television; - [underlined: Eating management:] techniques specifically aimed at modifying the act of eating, such as eating slowly; - [underlined: Contingency management:] contingency contracting, where rewards are given for desired eating or exercise behaviors, weight loss, or treatment attendance; - [underlined: Cognitive-behavioral techniques:] the attempt to alter maladaptive cognitions related to health behaviors, such as problem-solving during high-risk situations
Parent participation; - [underlined: High:] family participated in all aspects of treatment including attending treatment sessions, dietary choices, and behavioral modification techniques; - [underlined: Medium:] family involved in many components of treatment, but the child was solely responsible for some significant aspects of treatment, such as dietary choices; - [underlined: Low:] parents were minimally involved in treatment such as attending some sessions and providing encouragement

## References

1 Haddock CK, Shadish WR, Klesges RC, Stein RJ. Treatments for childhood and adolescent obesity. Ann Behav Med. 1994;16(3):235-244.
2 Not included in Haddock et al 1994.