# Appendix N. Screening and Intervention for Overweight in Children and Adolescents Categorization Scheme for Settings

The existing systematic evidence reviews of the childhood obesity literature have categorized the study settings as follows: school-based, clinical, or community-based. These interventions may or may not involve parents, may target individuals or groups, and vary in intensity and duration.

We have developed the diagram below to clarify which types of interventions are within the scope of the U.S. Preventive Services Task Force (USPSTF), the Community Task Force (CTF), or both. Most of the studies evaluated in the Cochrane review of treatment were set in specialist/research clinics and thus fall under clinical primary care referral interventions. In contrast, studies in the Cochrane review of obesity prevention were set in schools and fall under community non-referral. The diagram indicates which settings are of primary or secondary relevance for clinicians. Once refined, such an approach could be used to illustrate settings for reviews of other preventive topics relevant to clinicians, or for other audiences in addition to clinicians, such as health departments.

Criteria for Interventions Judged to Be Relevant/Feasible to Primary Care

[underlined: WHO TARGETED] : Somehow involve individual-level identification of being a patient/in need of intervention
[underlined: WHO DELIVERED] : Usually involve primary care clinicians (physicians in family practice, internal medicine, ob-gyn, pediatrics, general practitioner), other physicians, nurses, nurse practitioners, physician assistants or related clinical staff (dietitians, health educators, other counselors) in some direct or indirect way—or, at least, the intervention would be seen as connected to the health care system by the participant.
[underlined: HOW DELIVERED] : To individuals or in small groups (15 or less). Do not involve only or primarily group-level interventions outside the primary care setting to achieve behavioral changes. Generally involve no more than 8 group sessions total, and intervention time period is no longer than 12 months.
[underlined: WHERE DELIVERED] : Could be delivered anywhere (including via the web, interactive technologies, in the home) if linked to primary care as above.