# Appendix M. Evidence Table: Intervention Study Characteristics

Study Reference | N Randomized Setting Country | Age % Male, % Non-White | Entry Wt Criteria | Mean Entry Wt | Group# | Weight Outcome | | | | Physiological Outcomes | Childhood Health Outcomes | Study Quality
| | | | | | Units of Measure | 6–8 mo | 12–18 mo | 24–30 mo
Pharmacologic
Berkowitz et al 2003 ^1^ | 82 adolescents | 13–17 | BMI 32–44 | BMI 37.8 (3.8); BMI z-score: 2.4 (0.2) | #1: Sibutramine | change in BMI (% change from entry BMI) | -8.5% | N/A | NR | lipids yes; glucose tolerance yes; blood pressure yes; physical fitness NR | NR | Good
| University-based specialty research clinic | 33% | | | #2: Placebo | | -4.0% | N/A | NR
| USA | 45%
Low-glycemic load
Ebbeling et al 2003 ^2^ | 16 adolescents | 13–21 | BMI > 95%ile for sex, age | BMI 34.9 kg/m2 (reduced glycemic group); 37.1 kg/m2 (conventional diet group) | #1: Reduced glycemic load diet | absolute change in BMI | NR | -1.2 kg/m2 | NR | lipids NR; glucose tolerance yes; blood pressure NR; physical fitness NR | NR | Fair
| Research clinic | 31% | | | #2: Reduced fat diet | | NR | 0.6 kg/m2 | NR
| USA | 19%
Changes in physical activity
Epstein et al 1985a ^3^ | 41 families | 8–12 | > 20% over ideal weight for height, age, sex | 48% overweight | #1: aerobic PA | % overweight change | -17.4% | -16.3% | -6.8% | lipids NR; glucose tolerance NR; blood pressure NR; physical fitness yes | NR | Fair
| NR; presumably a research clinic | 40% | | | #2: lifestyle PA | | -19.6% | -16.1% | -18.0%
| USA | NR | | | #3: low-intensity calisthenics PA | | -20.7% | -17.5% | -7.2%
Epstein et al 1985b ^4^ | 23 children | 8–12 | at least 20% overweight for height and age | 48 % overweight for age and height | #1: diet + PA | % overweight change | -27.5% | -25.4% | NR | lipids NR; glucose tolerance NR; blood pressure NR; physical fitness yes | NR | Fair
| NR; presumably a research clinic | 0% | | | #2: diet alone | | -18.8% | -18.7% | NR
| USA | NR
Epstein et al 1995 ^5^ | 61 families | 8–12 | 20–100% overweight | 51.8% overweight | #1: increased PA | % overweight change | NR | -18.7% | NR | lipids NR; glucose tolerance NR; blood pressure NR; physical fitness yes | NR | Fair
| NR; presumably a research clinic | 27% | | | #2: decreased sedentary behavior | | NR | -10.3% | NR
| USA | 4% | | | #3: combined | | NR | -8.7% | NR
Epstein et al 2000b ^6^ | 90 families | 8–12 | 20–100% overweight | 62% overweight | #1: PA low dose | % overweight change | -25.6% | NR | -12.4% | lipids NR; glucose tolerance NR; blood pressure NR; physical fitness yes | NR | Fair
| Childhood obesity research clinic | 32% | | | #2: PA high dose | | -26.4% | NR | -13.2%
| USA | NR | | | #3: decreased sedentary behavior low dose | | -22.4% | NR | -11.6%
| | | | | #4: decreased sedentary behavior high dose | | -27.4% | NR | -14.3%
Gutin et al ^7^ /Kang et al ^8^ 2002 | 80 | 13–16 | triceps skinfold thickness > 85%ile for sex, ethnicity, and age | 40.7 % body fat (white boys); | #1: lifestyle education only (LSE) | change in % body fat | -0.1% | NR | NR | lipids yes; glucose tolerance yes; blood pressure yes; physical fitness yes | NR | Fair-to-Poor
| Research clinic | 33% | | 45.8% body fat (white girls); | #2: LSE + moderate PA | | -1.4% | NR | NR
| USA | 69% | | 43.9% body fat (black boys); | #3: LSE + high intensity PA | | -2.9% | NR | NR
| | | | 45.2% body fat (black girls)
Epstein et al 2001 ^9^ | 67 families | 8–12 | at or > 85%ile BMI for age and sex and < 100% over the average BMI for age and sex | 60.2% overweight (compared to the 50%ile BMI for age and sex); | #1: increased PA | change in absolute BMI | reported graphically | girls: -0.27 kg/m2; boys: -1.76 kg/m2 | NR | lipids NR; glucose tolerance NR; blood pressure NR; physical fitness NR | NR | Fair
| NR; presumably a research clinic | 52% | | BMI 27.4 kg/m2 (3.6 kg/m2) | #2: increased PA + decreased SB | | reported graphically | girls: 1.0 kg/m2; boys: -1.76 kg/m2 | NR
| USA | NR
Problem solving vs. usual care or behavioral therapy
Graves et al 1988 ^10^ | 40 children | 6–12 | at least 20% overweight for age, sex, and height | 52%–56% overweight for age, sex, and height | #1: BT + parent problem solving | % overweight change | -24.5% | NR | NR | lipids NR; glucose tolerance NR; blood pressure NR; physical fitness NR | NR | Fair
| NR; presumably a research clinic | NR | | | #2: BT only | | -10.2% | NR | NR
| USA | NR | | | #3: instruction only | | -9.5% | NR | NR
Epstein et al 2000a ^11^ | 67 children | NR, mean (sd) 10.3 (1.1) yrs | > 20% overweight | BMI 27.4 (3.2) | #1: PS to parent and child | change in absolute weight (kg) (analyzed change in BMI z-score) | -6.8 kg | -1.2 kg | 11.9 kg | lipids NR; glucose tolerance NR; blood pressure NR; physical fitness NR | problem behaviors | Fair
| NR; presumably a research clinic | 48% | | | #2: PS to child only | | -7.0 kg | -2.4 kg | 7.2 kg
| USA | 4% (2% black, 2% Hispanic) | | | #3: no PS | | -6.2 kg | -1.3 kg | 7.2 kg
Behavioral therapy vs no treatment/usual care
Epstein 1985c ^12^ | 24 children | 5–8 | No details given | 39–42% overweight | #1: BT | % overweight change | -23.7% | -26.3% | NR | lipids NR; glucose tolerance NR; blood pressure NR; physical fitness NR | NR | Fair
| NR; presumably a research clinic | 0% | | | #2: Education only | | -11.6% | -11.2% | NR
| USA | NR
Senediak and Spence 1985 ^13^ | 45 children | 6–13 | at least 20% overweight for height, age, and sex | 37.22% overweight | #1: rapid schedule BT | % overweight change | -14.7% | NR | NR | lipids NR; glucose tolerance NR; blood pressure NR; physical fitness NR | NR | Fair-to-Poor
| NR; presumably a research clinic | approximately 66% | | | #2: gradually decreasing schedule BT | | -18.3% | NR | NR
| USA | NR | | | #3: non-specific treatment controls | | -10.9% | NR | NR
| | | | | #4: wait list controls | | NR | NR | NR
Mellin et al 1987 ^14^ | 66 adolescents | 12–18 | No details given | 30–37% overweight for age, sex, and height | #1: SHAPEDOWN group (Cognitive, behavioral, affective treatment) | % overweight change | NR | -9.9% | NR | lipids NR; glucose tolerance NR; blood pressure NR; physical fitness NR | depression; self-esteem | Fair
| Rural health dept; rural nutrition private practice, suburban medical clinic; urban outpatient clinic | 21% | | | #2: no treatment controls | | NR | -0.1% | NR
| USA | 22%
Flodmark et al 1993 ^15^ | 44 children (plus 50 matched controls) | 10–11 | BMI > 23.0 kg/m^2^ | 25.5 kg/m^2^ (conventional treatment group); 24.7 kg/m^2^ (family therapy group): 25.1 kg/m^2^ (control group);similar to 40–50% overweight range | #1: conventional treatment | change in BMI (kg/m^2^) | NR | 0.6 kg/m^2^ | 1.6 kg/m^2^ | lipids NR; glucose tolerance NR; blood pressure NR; physical fitness yes | NR | Fair
| Outpatient referral clinical setting | 48% | | | #2: family therapy | | NR | 0.3 kg/m^2^ | 1.1 kg/m^2^
| Sweden | NR (Swedish) | | | #3: matched controls - untreated | | NR | NR | 2.8 kg/m^2^
Saelens et al 2002 ^16^ | 44 | 12–16 | 20–100% above median (50%ile) for BMI for sex and age | BMI 30.7 (3.1); | #1: Healthy habits intervention | % overweight change & change in BMI | -2.4%, 0.1 kg/m2 | NR | NR | lipids NR; glucose tolerance NR; blood pressure NR; physical fitness NR | eating disorder psychopathology (adverse effect) | Good
| Primary care clinical setting | 59% | | | #2: Typical care | | 4.1%, 1.4 kg/m2 | NR | NR
| USA | 30%
White 2003 ^17^ / Williamson unpublished data | 57 adolescents | 11–15 | BMI > 85th %ile for age and gender | BMI 36.34 kg/m^2^; 98.3 BMI %ile | #1: Behavioral | change in % body fat; change in BMI | -1.12%; -0.19 kg/m2 | NR | NR | lipids NR; glucose tolerance NR; blood pressure NR; physical fitness NR | depression, self-esteem, satisfaction with life, and eating disorder pathology measured but change over time NR | Good
| research clinic | 0% | | | #2: Education only | | 0.43%; 0.65 kg/m2 | NR | NR
| USA | 100%
Varying degrees of family involvement
Israel and Shapiro 1985 ^18^ | 33 children | 8–12 | at least 20% overweight for height | 53.13% overweight (BT only); 45.88% (parent training group); 56.02% (controls) | #1: BT only | % overweight change | NR | -1.3% | NR | lipids NR; glucose tolerance NR; blood pressure NR; physical fitness NR | NR | Fair-to-Poor
| NR; presumably a research clinic | 30% | | | #2: BT + parent training in child management | | NR | -10.2% | NR
| USA | NR | | | #3: wait list controls | | NR | NR | NR
Wadden et al 1990 ^19^ | 47 girls | 12–16 | > 10 kg overweight for age, sex, and height | 95.1 kg; BMI 35.6 kg/m^2^ | #1: child alone | change in weight | 3.0 kg | NR | NR | lipids yes; glucose tolerance NR; blood pressure yes; physical fitness NR (physiological outcomes at 4 mo) | self-esteem; depression (reported at 4 mo) | Fair-to-Poor
| NR; presumably a research clinic | 0% | | | #2: mother and child together | | 1.7 kg | NR | NR
| USA | 100% black | | | #3: mother and child separate | | 3.5 kg | NR | NR
Israel et al 1994 ^20^ | 36 families | 8–13 | at least 20% overweight for weight, height, and sex | 46.0% overweight (standard treatment group); 48.1% (enhanced child involvement group) | #1: standard treatment (parents primarily responsible) | % overweight change | -12.5% | -0.8% | 0.064 | lipids NR; glucose tolerance NR; blood pressure NR; physical fitness NR | NR | Fair-to-Poor
| NR; presumably a research clinic | NR | | | #2: enhanced child involvement | | -15.6% | -5.8% | -4.8%
| USA | NR
Golan et al 1998 ^21^ | 60 children | 6–11 | > 20 % overweight for age, height and gender | 39.6% overweight (experimental group); 39.1% (conventional group) | #1: parents exclusive agents of change | % overweight change | NR | -14.7% | NR | lipids NR; glucose tolerance NR; blood pressure NR; physical fitness NR | NR | Fair
| NR; presumably a research clinic | 38% | | | #2: conventional: children responsible for own wt loss | | NR | -8.1% | NR
| Israel | NR (Israeli)
Cognitive behavioral therapy
Duffy and Spence 1993 ^22^ | 29 children | 7–13 | > 15% overweight for age, ht and sex | 48.4% overweight | #1: BT + cognitive self-management | % overweight change | -8.9% | NR | NR | lipids NR; glucose tolerance NR; blood pressure NR; physical fitness NR | NR | Fair-to-Poor
| NR; presumably a research clinic | 21% | | | #2: BT + relaxation placebo | | -9.2% | NR | NR
| Australia | NR, Australian
Mastery criteria
Epstein et al 1994 ^23^ | 44 families | 8–12 | 20–100% overweight for height | 59.6% over the 50th%ile for BMI (equivalent to > 95%ile BMI for age; similar to 50–60% overweight range) | #1: mastery criteria & contingent reinforcement group | % overweight change | -30.1% | -26.5% | -15.4% | lipids NR; glucose tolerance NR; blood pressure NR; physical fitness NR | NR | Fair
| NR; presumably a research clinic | 26% | | | #2: comparison group | | -20.6% | -16.7% | -10.6%
| USA | NR

## References for Appendix M

1 Berkowitz RI, Wadden TA, Tershakovec AM, Cronquist JL. Behavior therapy and sibutramine for the treatment of adolescent obesity: a randomized controlled trial. JAMA. 2003;289(14):1805-1812. [pmid: 12684359].
2 Ebbeling CB, Leidig MM, Sinclair KB, Hangen JP, Ludwig DS. A reduced-glycemic load diet in the treatment of adolescent obesity. Archives of Pediatrics & Adolescent Medicine. 2003;157(8):773-779. [pmid: 12912783].
3 Epstein LH, Wing RR, Koeske R, Valoski A. A comparison of lifestyle exercise, aerobic exercise, and calisthenics on weight loss in obese children. Behavior Therapy. Sep. 1985;Vol 16(4):345-356.
4 Epstein LH, Wing RR, Penner BC, Kress MJ. Effect of diet and controlled exercise on weight loss in obese children. J Pediatr. 1985;107(3):358-361. [pmid: 4032130].
5 Epstein LH, Valoski AM, Vara LS, McCurley J, Wisniewski L, Kalarchian MA, et al. Effects of decreasing sedentary behavior and increasing activity on weight change in obese children 3814. Health Psychology. 1995;14(2):109-115. [pmid: 7789345].
6 Epstein LH, Paluch RA, Gordy CC, Dorn J. Decreasing sedentary behaviors in treating pediatric obesity. Arch Pediatr Adolesc Med. 2000;154(3):220-226. [pmid: 10710017].
7 Gutin B, Barbeau P, Owens S, Lemmon CR, Bauman M, Allison J, et al. Effects of exercise intensity on cardiovascular fitness, total body composition, and visceral adiposity of obese adolescents. American Journal of Clinical Nutrition. 2002;75(5):818-826. [pmid: 11976154].
8 Kang HS, Gutin B, Barbeau P, Owens S, Lemmon CR, Allison J, et al. Physical training improves insulin resistance syndrome markers in obese adolescents. Medicine & Science in Sports & Exercise. 2002;34(12):1920-1927. [pmid: 12471297].
9 Epstein LH, Paluch RA, Raynor HA. Sex differences in obese children and siblings in family-based obesity treatment. Obesity Research. 2001;9(12):746-753. [pmid: 11743058].
10 Graves T, Meyers AW, Clark L. An evaluation of parental problem-solving training in the behavioral treatment of childhood obesity. J Consult Clin Psychol. 1988;56(2):246-250. [pmid: 3372833].
11 Epstein LH, Paluch RA, Gordy CC, Saelens BE, Ernst MM. Problem solving in the treatment of childhood obesity. Journal of Consulting & Clinical Psychology. 2000;68(4):717-721. [pmid: 10965646].
12 Epstein LH. Effects of family-based behavioral treatment on obese 5-to-8-year-old children. Behavior Therapy. Mar. 1985;Vol 16(2):212.
13 Senediak C, Spence SH. Rapid versus gradual scheduling of therapeutic contact in a family based behavioural weight control programme for children. Behavioural Psychotherapy. Oct. 1985;Vol 13(4):287.
14 Mellin LM, Slinkard LA, Irwin CE Jr. Adolescent obesity intervention: validation of the SHAPEDOWN program 3987. Journal of the American Dietetic Association. 1987;87(3):333-338. [pmid: 3819254].
15 Flodmark CE, Ohlsson T, Ryden O, Sveger T. Prevention of progression to severe obesity in a group of obese schoolchildren treated with family therapy. Pediatrics. 1993;91(5):880-884. [pmid: 8474806].
16 Saelens BE, Sallis JF, Wilfley DE, Patrick K, Cella JA, Buchta R. Behavioral weight control for overweight adolescents initiated in primary care. Obesity Research. 2002;10(1):22-32. [pmid: 11786598].
17 White MA. Mediators of weight loss in an internet-based intervention for African-American adolescent girls. Louisiana State University, 2003.
18 Israel AC, Shapiro LS. Behavior problems of obese children enrolling in a weight reduction program. J Pediatr Psychol. 1985;10(4):449-460. [pmid: 4093833].
19 Wadden TA, Stunkard AJ, Rich L, Rubin CJ, Sweidel G, McKinney S. Obesity in black adolescent girls: a controlled clinical trial of treatment by diet, behavior modification, and parental support 3928. Pediatrics. 1990;85(3):345-352. [pmid: 2304788].
20 Israel AC, Guile CA, Baker JE, Silverman WK. An evaluation of enhanced self-regulation training in the treatment of childhood obesity. Journal of Pediatric Psychology. 1994;19(6):737-749. [pmid: 7830214].
21 Golan M, Fainaru M, Weizman A. Role of behaviour modification in the treatment of childhood obesity with the parents as the exclusive agents of change. Int J Obes Relat Metab Disord. 1998;22(12):1217-1224. [pmid: 9877257].
22 Duffy G, Spence SH. The effectiveness of cognitive self-management as an adjunct to a behavioural intervention for childhood obesity: a research note. J Child Psychol Psychiatry. 1993;34(6):1043-1050. [pmid: 8408368].
23 Epstein LH, McKenzie SJ, Valoski A, Klein KR, Wing RR. Effects of mastery criteria and contingent reinforcement for family-based child weight control 3838. Addictive Behaviors. 1994;19(2):135-145. [pmid: 8036961].