# Appendix J. Childhood Overweight Clinical Screening Tests and Predicting Adult Obesity

## Prior Reviews

A fair-quality systematic evidence review identified one previous review article representing international literature through 1992 ^1^ and identified six reports addressing obesity persistence from childhood into adulthood. ^2^ The systematic review indicated a tendency for childhood overweight to persist, particularly in older children, in overweight children with one or more obese parents, and in children with more severe overweight. ^2^ Quantitative relationships between childhood overweight measures and adult obesity measures were not systematically reported. Another non-systematic but extensive review through 1996 identified 25 longitudinal studies worldwide examining the relationship between childhood and adult adiposity. ^3^ Persistence (tracking) of adiposity from childhood and adolescence to adulthood varied with the measure of adiposity, the cutoff used to define overweight/obesity, the age of childhood assessment, and the age at which adulthood overweight/obesity was assessed. ^3^ In restricting their analysis to large British cohort studies, less variability was seen in the risk estimations, perhaps due to reduced variation in cutoff values used. Relative risks for adult obesity at age 33 years were higher for boys (7.0, 95% CI 5.7–8.4) and girls (5.5, 95% CI 4.8–6.4) with BMIs over the 98^th^ percentile at age 16, than for boys and girls aged 7 with the same BMI (4.2, 95% CI 3.3–5.5 and 4.2, 95% CI 3.5–5.0, respectively). Similarly, correlations for BMI and other indices of adiposity were higher (0.46–0.91 in males and 0.60–0.78 in females) between adolescence and young adulthood than for younger ages (r of about 0.30). BMI between childhood and adulthood was more strongly correlated than skinfolds or waist:hip ratio. Few studies examined the impact of change in adiposity in childhood or timing of adiposity rebound. However, the majority of obese adults were not fat in childhood or adolescence. For example, in a 1958 British birth cohort, 13% and 11% of obese 33-year-old men and women were overweight at age 16, but only 8% and 9% were overweight at age seven. The authors concluded that, while adiposity tracks from childhood—particularly from adolescence-to adulthood, the prevention of adult obesity cannot rely solely on identification of a high-risk group in childhood. ^3^

## Longitudinal U.S. Studies

We examined 19 fair- or good-quality retrospective or prospective observational studies (in 20 publications) from the United States (Table J-1) reporting on the relationship of different childhood overweight measures (BMI values or percentiles), ponderal index (values or percentiles), skinfolds (triceps and/or subscapular), and/or relative weight (one study) to adult measures of overweight and obesity (usually based on BMI or skinfolds). Few studies used ponderal index or relative weight. Studies that compared ponderal index or skinfolds to BMI showed consistent superiority for BMI in measurement correlations between childhood and adulthood (Table J-1). Since these measures are not as widely used clinically and have not been shown to be superior to BMI, which was confirmed in the studies reviewed here, we limit our discussion to BMI values or percentiles. Studies used a variety of reference populations for age- and sex-specific childhood BMI percentiles, including some listed in Appendix R and the 2000 CDC sex-specific BMI-for-age charts, and also used several definitions for adult overweight based on BMI.

## General Trends in the Data

Tracking. Across a normal range of childhood BMI levels, early adult (37 years or less) BMI levels tend to correlate more strongly with childhood BMI levels measured at older ages than younger ages, and slightly better in boys than girls. ^4^ With a few exceptions, BMI at age 12 or above correlated above 0.6 with adult values up to age 37 in white boys and girls, with somewhat lower values generally (but not always) seen in girls. One study among black children showed strikingly lower correlations of childhood BMI at ages 7 and 14 ^5^ compared with whites. Another study showed better correlation of BMI at ages 4–7 and ages 13–17 with adult BMI in black children than in whites, particularly in adolescent black females. ^6^ Because of the way the data were reported, many studies did not contribute much to the understanding of differences in the strength of the relationship between childhood and adulthood at different ages. This is particularly true for non-BMI measures, such as triceps skinfold (TSF). Correlations of TSF measures in childhood and adulthood were not available for those between two and nine, except in a small study ^7^ in which very modest correlations (0.35 for boys and 0.18 for girls) were seen between TSF at or above the 85th percentile at age seven and the same value at age 25. In studies that reported both BMI and TSF in white boys and girls (ages 9–18) and in adulthood (ages 20–35), TSF had lower correlations (0.26–0.58) than BMI (0.58–0.91) with the same adult measure, ^8^ across all ages and in boys as well as girls.

Risks or odds of overweight in adulthood. No large U.S. studies provide relative risks for adult obesity across the age ranges 2–18 years. Guo et al 1994 ^9^ compiled data from four cohort studies and computed the relative risk (RR) of overweight at age 35 (BMI >28 in males and >26 in females) in white adults who were measured in the age-specific 95^th^ percentile of BMI or more vs. the 75^th^ percentile or less at ages 3, 8, 13, and 18 years. RRs did not differ significantly between boys and girls and were modest, with non-significant trends upward with age (1.37 at age 3, 2.03 at age 8, 2.57 at age 18, and 6.05 at age 18 in boys). Statistically significant differences were seen only between those at age 18 and those at age 8 or younger.

In a retrospective HMO medical record cohort study, much higher odds (7.9 to 44.3) were seen for adult obesity (BMI 27.8 or greater for males and 27.3 or greater in females) at age 30 or younger for white adults whose childhood BMIs measured at or above the 95^th^ percentile compared to all others. ^10^ Odds ratios tended to increase non-significantly with age but with no statistically significant differences, due to very wide, overlapping 95% confidence intervals. Since this was not estimating a rare condition, odds ratios in this case are not comparable with relative risks. However, this study importantly indicated that parental obesity is an important moderator, as the odds of young adult overweight were at least doubled for non-obese and obese children at all ages when one or more parent was obese.

BMI changes over time. Few U.S. studies examine the impact of change in adiposity in childhood or timing of adiposity rebound in adult overweight, although experts have recently noted three times in childhood (prenatal period, period of adiposity rebound [AR], and adolescence) as potentially critical in overweight development. ^11^ (Adiposity rebound is the nadir of the longitudinal growth curve for an individual child occurring, on average, at 5–6 years). In a retrospective cohort study among predominately non-Hispanic white, primarily middle and upper-middle class, long-term HMO members, obesity rates in early adulthood (ages 21–29) were higher (25%) in children with earlier age (before 4.8 years) at AR compared to those with a later rebound (10%). ^12^ Controlling for the other factors associated with increased prevalence of early adult obesity (parental obesity, BMI at time of AR, and sex), boys and girls with early age at AR had an increased odds (6.0, 95% CI 1.3–26.6) of adult obesity compared with those whose AR occurred at 6.2 years or after. Paternal obesity and maternal obesity independently increased the odds of adult obesity in the offspring (OR 4.1, 95% CI 1.5–11.4 and OR 3.2, 95% CI 1.1–9.5, respectively).

Mean age of AR for boys and girls and correlations between age at AR and adult BMI were similar in this study and in a study of the older Fels longitudinal cohort consisting of mostly white individuals. ^13^ Using serial records of childhood weight and height measures in the Fels cohort, children who reached a BMI > 25 before age 25 compared to those who never did, or who reached it after age 25, were not reported to have an earlier age at adiposity rebound, but had a steeper slope of weight and increase in BMI after AR. ^14^ Particularly in girls who reached an adult overweight BMI before age 25, the BMI pattern from ages two through six showed little evidence of the usual decline and rebound seen in normal or later-onset overweight children. It should be noted that the adult definition of overweight (BMI > 25) was applied to these children, which corresponds to BMI percentile for both males and females in the 75–85^th^ percentile at age 18 for males (the mean age at which this BMI was reached), in the 90–95^th^ percentile at age 14 (one standard deviation), and substantially above the 95^th^ percentile at age 10 (two standard deviations). ^15^

Bogalusa Heart Study investigators confirmed the relationship between early AR (age five or before) and increased adult weight. However, this relationship was not independent of childhood BMI at age seven or eight years. ^4^ Exploratory analyses suggested that childhood height between the 25^th^ and 75^th^ percentile at age five appeared to modestly modify the relationship of childhood BMI at age 5 to young adult BMI.

Probability of adult obesity. Table J-1 examines the probability of adult obesity for children by BMI percentile at ages 3–18. For black and white children between 5 and 17 years of age, there is a low probability of adult obesity for those below the 50^th^ percentile. ^16^ For those between the 85^th^ and 94^th^ percentiles (at risk for overweight), about half were found to be obese at age 18–37. The probability of obesity was relatively high (0.7) for children who measured in the overweight category (BMI ≥95^th^ percentile) between ages 5 and 17 years. By combining age groups, these data do not tell us much about the differences in the probability of overweight between younger and older children with BMIs at the 95^th^ percentile or above. Data on whites only from the Fels longitudinal study (1929 through 1960) suggests that the probability of adult obesity at age 35 does not exceed 0.5 for children at any of the BMI cutpoints examined before age 13. ^17^ After age 13, white boys at the 95^th^ percentile or above had a relatively high probability of adult obesity (0.5–0.8), with similar results for white girls (0.64–0.68). This was not a large sample, and there were no confidence intervals reported for these estimates. Looking at the same sample another way, researchers found very poor sensitivity and moderate specificity for the “optimal” BMI cutpoint (based on maximizing the area under the curve) of the 72^nd^ percentile at age 18 for detecting those that became obese at age 35. Of note, based on analysis of a series of ROC curves, the best overall test performance using BMI percentiles to “screen” for adult obesity was in children aged 18.

Children aged 2–5. There is limited data on tracking. A study of 555 white three-year-olds with mean BMI of 16 (1.2) for males and 16 (1.4) for females (around the 50th percentile) ^15^ found a poor correlation with overweight at age 35 (defined as BMI >28 in males and BMI >26 in females) with r = 0.18 and 0.22 in males and females, respectively. ^9^ In the same study, three-year-old boys and girls at the 95^th^ percentile (NHANES II) had only a 0.2 probability of overweight at age 35. Using a portion of the same cohort (n=347) in a later study using CDC growth chart definitions for childhood BMI percentiles, ^17^ children in the 95^th^ percentile for BMI at age three had a 0.2–0.24 probability of adult obesity (BMI 30 or greater), but a much higher probability (0.7 in males and 0.58 in females) of being overweight (BMI 25 or greater). This series of reports over time (from the same research group using essentially the same set of data) illustrates that no matter what BMI-based definition is used for childhood overweight, the tracking into adulthood for this age is minimal. However, the apparent probability of overweight varied substantially (from 0.18 to 0.7 in males and from 0.22 to 0.58 in females) depending on how broadly adulthood overweight was defined.

In a commonly cited separate study addressing predominantly white three- to six-year-old boys and girls, those with BMIs in the 85^th^ percentile or above (NHANES I-II) had an increased risk of overweight (BMI 27.8 or above in males and 27.3 or above in females) (RR of 4.1, 95% CI 2.5–6.7). ^10^ These elevated relative risks can be somewhat misleading when absolute risk information is not also presented. The absolute risk here was 19% (14 of 73 children with BMIs at the 85^th^ percentile or above became overweight as adults). For young children above the 95^th^ percentile, 52% (14/27) were overweight at age 35.

Children aged 6–11. Tracking data between childhood and adult BMI measures that have been examined for children aged 3–7, 4–7, 7–8, and 9–10 are relevant to this age group. In general, correlations between BMIs measured in predominantly white 6–11-year-olds and again as adults up to age 37 range from 0.36 to 0.73 in males and from 0.21 to 0.63 in females. The few comparable studies done in blacks suggest correlations between 0.28 and 0.68 in males and 0.28 and 0.65 in females. There is not enough data to clearly determine racial/ethnic differences. Considering probability of adult obesity from BMI measures at this age, limited data in whites suggest a probability at or below 0.5. Higher probabilities were reported for overweight (defined as BMI > 27) in black and white boys at age 10 from the Bogalusa Heart Study. Boys with BMI values of 18 had about a 0.5 probability of overweight 15 years later, as did girls with BMI values of 20 (white girls) and 17 (black girls). These BMI values convert to about the 75^th^ percentile for black and white boys, the 85^th^ percentile for white girls, and the 50^th^ percentile for black girls on the 2000 CDC growth charts. ^15^

Adolescents aged 12–18. Tracking between childhood and adulthood in weight-for-height measures such as BMI increases ^18^ with attainment of peak height. ^19^ Therefore it makes sense that adolescents will generally show higher levels of BMI tracking than younger children. However, the data between studies show a range of results, depending on the age of adolescents measured and the age of measurement in adulthood. Presumably some of this variability also reflects a mixture of pubertal stages in younger adolescents. By age 17–18, most children can be assumed to have gone through puberty. BMIs in white children aged 17–18 years correlate with adult BMIs up to age 35 between 0.58 and 0.81 for males and 0.63 to 0.81 for females. ^19^ – ^22^ Data for black children separately are limited to boys and girls at age 13 and 14 ^5^ or 13–17. ^6^ In these studies, young black adolescents' BMIs correlated 0.37–0.72 with their BMIs at age 28–32. These values were the same or better than the correlation in white children in the only study that measured and reported results for both black and white children. ^6^ Considering probability of adult overweight, there are more data available for this age group than for younger children. After age 13, white boys at or above the 95^th^ percentile had a relatively high probability of adult obesity (0.5–0.8), with similar results for white girls (0.64–0.68). The Bogalusa Heart Study found that boys with BMI values of 22 had about a 0.5 probability of overweight 15 years later, as did girls with BMI values of 25 (white girls) and 23 (black girls). ^23^ Using the CDC 2000 charts, these BMI values convert to the 75^th^ percentile for boys, between the 85^th^ and 90^th^ percentiles for white girls, and between the 75^th^ and 85^th^ percentiles for black girls.

Table J-1 Evidence Table: Relationship between Childhood Overweight and Adult Overweight

Author QUALITY | N | % White | % Female | Age | | OW Defined as | | | M | F | Measure | Reference Standard
| | | | Initial | Follow-up | Youth | BMI Range (Youth) | Adult
BMI (kg/m^2^): continuous
Freedman et al 2004 ^4^ | 885 | 67% overall; NR for this age group | 62% | 3 to 7 | 18 to 37 (mean: 25) | BMI | NR: mean BMI for study pop is 17.7+/-3.4 | BMI | 0.59 | 0.51 | Correlation | N/A
FAIR | | | | | | | | TSF + SSF (sum) | 0.47 | 0.38
Wattigney et al 1995 ^6^ | 222 | 100% | 57% | 4 to 7 | 19 to 22 | BMI | NR | BMI | 0.43 | 0.43 | Correlation | N/A
FAIR | 132 | 100% black | 58% | | | | | | 0.68 | 0.65
Casey et al 1992a ^19^ | 114 | 100% | 50% overall; NR this age group | 5 to 7 | 30 | BMI | Mean BMI: 15.4 +/- .9 (m); 15.7 +/- 1.5 (f) | BMI | 0.41 | 0.21 | Correlation | N/A
FAIR | 104 | | | | 40 | | | | 0.36 | -0.03
| 84 | | | | 50 | | | | 0.41 | 0.05
Freedman et al 2001 ^16^ | 2617 | 67% white, 32% black | 57% | 5 to 17 | 18 to 37 | BMI | Mean childhood BMI: 17.8 +/- 3.5 | BMI | 0.58 | | Correlation | N/A
FAIR
Hulman et al 1998b ^5^ | 137 | 0% white; 100% black | 49% | 7 | 28 | BMI | Mean BMI 16.7 +/-3.0 (m); 16.4 +/- 2.4 (f) | BMI | 0.28 | | Correlation | N/A
FAIR
Sinaiko et al 1999 ^24^ | 679 | 66% white, 25% black, 4% NA | 48% | 8 | 24 | BMI | 8 to 34 | BMI | 0.612 | | Correlation | N/A
FAIR
Freedman et al 2004 ^4^ | 2444 | 67% overall; NR for this age group | 56% | 8 to 13 | 18 to 37 | BMI: continuous | NR: mean BMI for study pop is 17.7+/-3.4 | BMI (continuous) | 0.68 | 0.63 | Correlation | N/A
FAIR | | | | | | | | TSF + SSF (sum) | 0.53 | 0.49
Valdez et al 1996d ^23^ | 835 | 68% | 54% | 10 to 15 | 25 to 30 | BMI | Means: 19.1+/- .23 (wm); 18.5 +/-0.33 (bm); 18.9 +/-0.21 (wf); 19.6 +/-0.30 (bf) | BMI > 27 | 0.64 | | Correlation | N/A
FAIR | | | | | | | | | 1.65 (1.48–1.84) | 1.58 (1.43–1.74) | RR or OR
Hulman et al 1998b ^5^ | 137 | 100% black | 49% | 13 | 28 | BMI | Mean BMI 19.7 +/- 4.1 (m); 20.6 +/- 4.2 (f) | BMI | 0.37 | | Correlation | N/A
FAIR
Wattigney et al 1995 ^6^ | 327 | 100% | 51% | 13 to 17 | 28 to 32 | BMI: kg/m^2^ | NR | BMI: kg/m^2^ | 0.63 | 0.48 | Correlation | N/A
FAIR | 147 | 100% black | 55% | | | | | | 0.69 | 0.72
Hulman et al 1998b ^5^ | 137 | 100% black | 49% | 14 | 28 | BMI | Mean BMI 20.4 +/- 4.4 (m); 22.2 +/- 4.8 (f) | BMI | 0.13 | | Correlation | N/A
FAIR
Freedman et al 2004 ^4^ | 2212 | 67% overall; NR for this age group | 56% | 14 to 17 | 18 to 37 | BMI: continuous | NR: mean BMI for study pop is 17.7+/-3.4 | BMI: continuous | 0.76 | 0.73 | Correlation | N/A
FAIR | | | | | | | | TSF + SSF sum | 0.57 | 0.56
Casey et al 1992 ^19^ | 95 | 100% | 50% overall; NR this age group | 18 | 30 | BMI (W/H^2^) | Mean BMI: 21.3 +/- 1.9 (m); 20.7 +/- 2.6 (f) | BMI (W/H^2^) | 0.67 | 0.66 | Correlation | N/A
FAIR | 84 | | | | 40 | | | | 0.61 | 0.62
| 67 | | | | 50 | | | | 0.51 | 0.44
BMI %ile (kg/m^2^): continuous
Guo et al 1994 ^9^ | 555 | 100% | 50% | 3 | 35 | BMI | Mean baseline BMI range: 16+/-1.2 (3 yo m) to 25 +/- 3.4 (18 yo m); 16+/- 1.4 (3 yo f) to 26 +/- 5.0 (18 yo f) | BMI | 0.18 | 0.22 | Correlation | N/A
FAIR
Lauer et al 1988, Lauer and Clarke 1989 ^20,^ ^21^ | 109 obs | 100% | 52% | 7 to 8 | 20 to 25 | W/H^2^: assume kg/m^2^ | Approx 17 | W/H^2^ (QI): assume kg/m^2^ | 0.57 | 0.45 | Correlation | N/A
FAIR
Guo et al 1994 ^9^ | 555 | 100% | 50% | 8 | 35 | BMI | Mean baseline BMI range: 16+/-1.2 (3 yo m) to 25 +/- 3.4 (18 yo m); 16+/- 1.4 (3 yo f) to 26 +/- 5.0 (18 yo f) | BMI | 0.28 | 0.60 | Correlation | N/A
FAIR
Clarke and Lauer 1993c ^22^ | 1286 obs | 100% | 53% | 9 to 10 | 21 to 25 | BMI | Baseline NR | BMI | 0.61 | 0.59 | Correlation | N/A
FAIR | 304 obs | | 58% | | 26 to 30 | | | | 0.73 | 0.6
Lauer et al 1988, Lauer and Clarke 1989 ^20,^ ^21^ | 603 obs | 100% | 52% | 9 to 10 | 20 to 25 | W/H^2^: assume kg/m^2^ | Approx 18 | W/H^2^ (QI): assume kg/m^2^ | 0.63 | 0.61 | Correlation | N/A
FAIR
Lauer et al 1997 ^8^ | 2631 | 100% | NR | 9 to 18 | 23 to 33 | BMI | NR | BMI | .58 – .91 | | Correlation | N/A
FAIR
Lauer et al 1988, Lauer and Clarke 1989 ^20,^ ^21^ | *1018 obs | 100% | 53% | 11 to 12 | 20 to 25 | W/H^2^: assume kg/m^2^ | Approx 20 | W/H^2^ (QI): assume kg/m^2^ | 0.67 | 0.65 | Correlation | N/A
FAIR
Guo et al 1994 ^9^ | 555 | 100% | 50% | 13 | 35 | BMI | Mean baseline BMI range: 16+/-1.2 (3 yo m) to 25 +/- 3.4 (18 yo m); 16+/- 1.4 (3 yo f) to 26 +/- 5.0 (18 yo f) | BMI | 0.50 | 0.65 | Correlation | N/A
FAIR
Lauer et al 1988, Lauer and Clarke 1989 ^20,^ ^21^ | 1041 obs | 100% | 53% | 13 to 14 | 20 to 25 | W/H^2^: assume kg/m^2^ | Approx 21 | W/H^2^ (QI): assume kg/m^2^ | 0.64 | 0.68 | Correlation | N/A
FAIR | | | | | 26 to 30 | | | | 0.74 | 0.67
Clarke and Lauer 1993c ^22^ | 1104 obs | 100% | 54% | 13 to 14 | 21–25 | BMI | Baseline NR | BMI | 0.7 | 0.7 | Correlation | N/A
FAIR | 713 obs | | 56% | | 26 to 30 | | | | 0.79 | 0.68
| 104 obs | | 52% | | 31–35 | | | | 0.91 | 0.77
Lauer et al 1988, Lauer and Clarke 1989 ^20,^ ^21^ | 767 obs | 100% | 54% | 15 to 16 | 20 to 25 | W/H^2^: assume kg/m^2^ | Approx 22 | W/H^2^ (QI): assume kg/m^2^ | 0.68 | 0.68 | Correlation | N/A
FAIR | 568 obs | | | | 26 to 30 | | | | 0.66 | 0.69
Clarke and Lauer 1993c ^22^ | 631 obs | 100% | 52% | 17 to 18 | 21 to 25 | BMI | Baseline NR | BMI | 0.81 | 0.72 | Correlation | N/A
FAIR | 676 obs | | 52% | | 26 to 30 | | | | 0.77 | 0.7
| 218 obs | | 51% | | 31–35 | | | | 0.58 | 0.63
Lauer et al 1988, Lauer and Clarke 1989 ^20,^ ^21^ | 615 obs | 100% | 51% | 17 to 18 | 20 to 25 | W/H^2^: assume kg/m^2^ | Approx 23 | W/H^2^ (QI): assume kg/m^2^ | 0.74 | 0.73 | Correlation | N/A
FAIR | 469 obs | | 52% | | 26 to 30 | | | | 0.68 | 0.52
Guo et al 1994 ^9^ | 555 | 100% | 50% | 18 | 35 | BMI | Mean baseline BMI range: 16+/-1.2 (3 yo m) to 25 +/- 3.4 (18 yo m); 16+/- 1.4 (3 yo f) to 26 +/- 5.0 (18 yo f) | BMI | 0.65 | 0.77 | Correlation | N/A
FAIR
BMI ≥ 95th %ile
Freedman et al 2001 ^16^ | 60 | 67% white, 32% black in whole pop | 57% overall; NR in this age group | < 8 | 18 to 37 | BMI ≥ 95%ile | N/A | BMI ≥ 30 | 87% | | % OC who became OA | CDC / NCHS growth charts for 1963-94
FAIR
Whitaker et al 1997 ^10^ | 27 | 94% overall | 64% overall; NR this age group | 3 to 5 | 21 to 29 | BMI ≥ 95%ile | N/A | BMI > 27.8 (m), 27.3 (f) | 7.9 (3.6 – 17.3) | | RR or OR | NHANES I-II
FAIR
Freedman et al 2001 ^16^ | 186 | 67% white, 32% black overall | 57% overall; NR in this age group | 5 to 17 | 18 to 37 | BMI ≥ 95%ile | N/A | BMI ≥ 30 | 77% | | % OC who became OA | CDC / NCHS growth charts for 1963-94
FAIR | 581 adults BMI > 30 | | | | | | | | 25% | - | % OA who were OC
Whitaker et al 1997 ^10^ | 35 | 94% overall, NR this age group | 64% overall, NR this age group | 6 to 9 | 21 to 29 | BMI ≥ 95%ile | N/A | BMI ≥ 27.8 (m), 27.3 (f) | 18.5 (8.8–38.8) | | RR or OR | NHANES I-II
FAIR | 29 | | | 10 to 14 | | | | | 44.3 (16.3 – 120)
| 30 | | | 15 to 17 | | | | | 32.5 (13.1 – 80.6)
Gortmaker et al 1993 ^25^ | 10,039; 56–79% follow up by question | 80% white, 14% black, 6% Hispanic full cohort | 100% | 16 to 24 | 23 to 31 | BMI > 95^th^ %ile for age, sex | N/A | BMI > 95^th^ %ile for age, sex | 77% | 66% | % OC who became OA | NHANES I
FAIR
BMI at 95th %ile
Guo et al 1994e ^9^ | 555 in whole cohort | 100% | 50% | 3 | 35 | BMI at the 95th %ile | N/A | BMI > 28 (m), > 26 (f) | 0.21 | 0.20 | Other | NHANES II
FAIR
Guo et al 2002e ^17^ | 347 whole cohort | 100% | 52% overall | 3 | 35 | BMI at the 95th %ile | N/A | BMI ≥ 25 | 0.71 | 0.58 | Other | CDC growth charts
FAIR | | | | | | | | BMI ≥ 30 | 0.15 | 0.24 | | NHANES I-III
Guo et al 1994e ^9^ | 555 in whole cohort | 100% | 50% | 8 | 35 | BMI at the 95th %ile | N/A | BMI > 28 (m), > 26 (f) | 0.37 | 0.39 | Other | NHANES II
FAIR
Guo et al 2002e ^17^ | 347 whole cohort | 100% | 52% overall | 8 | 35 | BMI at the 95th %ile | N/A | BMI ≥ 25 | 0.72 | 0.76 | Other | CDC growth charts
FAIR | | | | | | | | BMI ≥ 30 | 0.22 | 0.46 | | NHANES I-III
Guo et al 1994e ^9^ | 555 in whole cohort | 100% | 50% | 13 | 35 | BMI at the 95th %ile | N/A | BMI > 28 (m), > 26 (f) | 0.40 | 0.32 | Other | NHANES II
FAIR
Guo et al 2002e ^17^ | 347 whole cohort | 100% | 52% overall | 13 | 35 | BMI at the 95th %ile | N/A | BMI ≥ 25 | 0.91 | 0.92 | Other | CDC growth charts
FAIR | | | | | | | | BMI ≥ 30 | 0.46 | 0.64 | | NHANES I-III
Guo et al 1994e ^9^ | 555 in whole cohort | 100% | 50% | 18 | 35 | BMI at the 95th %ile | N/A | BMI > 28 (m), > 26 (f) | 0.78 | 0.66 | Other | NHANES II
FAIR
Guo et al 2002e ^17^ | 347 whole cohort | 100% | 52% overall | 18 | 35 | BMI at the 95th %ile | N/A | BMI ≥ 25 | 0.98 | 0.95 | Other | CDC growth charts
FAIR | | | | | | | | BMI ≥ 30 | 0.77 | 0.68 | | NHANES I-III
BMI 85th–94th %ile
Freedman et al 2001 ^16^ | 2617 | 67% white, 32% overall | 57% overall; NR in this age group | 5 to 17 | 18 to 37 | BMI 85–94th %ile | N/A | BMI ≥ 30 | 51% | | % OC who became OA | CDC / NCHS growth charts for 1963-94
FAIR | 581 adults BMI ≥ 30 | | | | | | | | 22% | - | % OA who were OC
BMI ≥ 85th %ile
Whitaker et al 1997 ^10^ | 86 | 94% overall | 64% overall | 3 to 5 | 21 to 29 | BMI ≥ 85^th^%ile | N/A | BMI ≥ 27.8 (m), 27.3 (f) | 4.1 (2.5–6.7) | | RR or OR | NHANES I-II
FAIR | NR:w/ parental data too (f) | | | | | | | | 4.7 (2.5 – 8.8)
| 80 | | | 6 to 9 | | | | | 10.3 (6.2 – 17.3)
| NR:w/ parental data too (f) | | | | | | | | 8.8 (4.7 – 16.5)
| 61 | | | 10 to 14 | | | | | 28.3 (15.0–35.5)
| NR:w/ parental data too (f) | | | | | | | | 22.3 (10.5 – 47.1)
| 55 | | | 15 to 17 | | | | | 20.3 (10.4–39.6)
| NR:w/ parental data too (f) | | | | | | | | 17.5 (7.7 – 39.5)
BMI at 85th %ile
Guo et al 2002e ^17^ | 347 whole cohort | 100% | 52% whole cohort | 3 | 35 | 85th %ile | N/A | BMI ≥ 25 | 0.59 | 0.45 | Other | CDC growth charts
FAIR | | | | | | | | BMI ≥ 30 | 0.12 | 0.17 | | NHANES I-III
| | | | 8 | | | | BMI ≥ 25 | 0.57 | 0.54
| | | | | | | | BMI ≥ 30 | 0.14 | 0.23
| | | | 13 | | | | BMI ≥ 25 | 0.71 | 0.66
| | | | | | | | BMI ≥ 30 | 0.22 | 0.27
| | | | 18 | | | | BMI ≥ 25 | 0.87 | 0.72
| | | | | | | | BMI ≥ 30 | 0.33 | 0.26
BMI ≥ 80th %ile (top quintile)
Clarke and Lauer 1993c ^22^ | 1286 obs | 100% | 53% | 9 to 10 | 21 to 25 | BMI ≥ 80th %ile | N/A | BMI ≥ 80th %ile | 62% | 65% | % OC who became OA | Muscatine study population
FAIR | 304 obs | | 58% | | 26 to 30 | | | | 65% | 65%
Lauer et al 1997 ^8^ | 2631 | 100% | NR | 9 to 18 | 23 to 33 | BMI ≥ 80th %ile | N/A | BMI ≥ 80th %ile | 48–75% | | % OC who became OA | age, sex, year specific %iles: study pop; also NHANES II
FAIR
Clarke and Lauer 1993c ^22^ | 1104 obs | 100% | 54% | 13 to 14 | 21 to 25 | BMI ≥ 80th %ile | N/A | BMI ≥ 80th %ile | 58% | 68% | % OC who became OA | Muscatine study population
FAIR | 713 obs | | 56% | | 26 to 30 | | | | 70% | 65%
| 104 obs | | 52% | | 31 to 35 | | | | 75% | 87%
| 631 obs | | 52% | 17 to 18 | 21 to 25 | BMI ≥ 80th %ile | N/A | BMI ≥ 80th %ile | 75% | 62% | | Muscatine study population
| 676 obs | | 52% | | 26 to 30 | | | | 65% | 59%
| 218 obs | | 51% | | 31 to 35 | | | | 62% | 50%
BMI > 75th %ile
Srinivasan et al 1996 ^26^ | 191 | 33% w m, 35% w f, 13% b m, 19% b f | NR | 13 to 17 | 27 to 31 | BMI > 75th %ile | N/A | BMI > 75th %ile: kg/m^2^ | 58% | | % OC who became OA | in-study
FAIR | | | | | | | | | 57%
| | 100% black | 0% | | | | | | 52% | -
| | 100% black | 100% | | | | | | - | 62%
BMI at 75th %ile
Guo et al 1994e ^9^ | 555 in whole cohort | 100% | 50% | 3 | 35 | BMI at the 75th %ile | N/A | BMI > 28 (m), > 26 (f) | 0.16 | 0.15 | Other | NHANES II
FAIR
Guo et al 2002e ^17^ | 347 whole cohort | 100% | 52% overall | 3 | 35 | BMI at the 75th %ile | N/A | BMI ≥ 25 | 0.53 | 0.38 | Other | CDC growth charts
FAIR | | | | | | | | BMI ≥ 30 | 0.1 | 0.14 | | NHANES I-III
Guo et al 1994e ^9^ | 555 in whole cohort | 100% | 50% | 8 | 35 | BMI at the 75th %ile | N/A | BMI > 28 (m), > 26 (f) | 0.23 | 0.20 | Other | NHANES II
FAIR
Guo et al 2002e ^17^ | 347 whole cohort | 100% | 52% overall | 8 | 35 | BMI at the 75th %ile | N/A | BMI ≥ 25 | 0.49 | 0.44 | Other | CDC growth charts
FAIR | | | | | | | | BMI ≥ 30 | 0.12 | 0.16 | | NHANES I-III
Guo et al 1994e ^9^ | 555 in whole cohort | 100% | 50% | 13 | 35 | BMI at the 75th %ile | N/A | BMI > 28 (m), > 26 (f) | 0.21 | 0.19 | Other | NHANES II
FAIR
Guo et al 2002e ^17^ | 347 whole cohort | 100% | 52% overall | 13 | 35 | BMI at the 75th %ile | N/A | BMI ≥ 25 | 0.58 | 0.48 | Other | CDC growth charts
FAIR | | | | | | | | BMI ≥ 30 | 0.15 | 0.16 | | NHANES I-III
Guo et al 1994e ^9^ | 555 in whole cohort | 100% | 50% | 18 | 35 | BMI at the 75th %ile | N/A | BMI > 28 (m), > 26 (f) | 0.37 | 0.32 | Other | NHANES II
FAIR
Guo et al 2002e ^17^ | 347 whole cohort | 100% | 52% overall | 18 | 35 | BMI at the 75th %ile | N/A | BMI ≥ 25 | 0.72 | 0.52 | Other | CDC growth charts
FAIR | | | | | | | | BMI ≥ 30 | 0.17 | 0.15 | | NHANES I-III
BMI > 72nd %ile
Guo et al 2002 ^17^ | 78 | 100% | 52% overall | 18 | 35 | ≥ 72nd %ile | N/A | BMI ≥ 30 | .36, sens / spec .83, .79 | .36, sens / spec .76, .83 | Other | CDC growth charts
FAIR | | | | | | | | | 19.3 (5.20, 71.4) | 15.7 (4.69, 52.5) | RR or OR | NHANES I-III
BMI ≥ 60th %ile
Guo et al 1994 ^9^ | 115 | 100% | 50% | 18 | 35 | BMI ≥ 60th %ile | N/A | BMI > 28 (m), > 26 (f) | 14.9 (5.01, 52.6) | 27.7 (7.35, 151.3) | RR or OR | NHANES II
FAIR | | | | | | | | | 0.34: sens .81, spec .77 | 0.37 (sens .86, spec .81) | Other
BMI at 60th %ile
Guo et al 1994 ^9^ | 115 | 100% | 50% | 18 | 35 | BMI at 60th %ile | N/A | BMI > 28 (m), > 26 (f) | false positive: 18% (m), 17% (f); sensitivity 80% | | Other | NHANES II
FAIR
BMI > 50th %ile
Freedman et al 2001g ^16^ | 2617 | 67% white, 32% black | 57% overall; NR in this age group | 5 to 17 | 18 to 37 | BMI < 50%ile | N/A | BMI ≥ 30 | 7% | | % OC who became OA | CDC / NCHS growth charts for 1963-94
FAIR
Freedman et al 2001h ^16^ | 581 adults BMI ≥30 | 67% white, 32% black in whole pop | 57% overall; NR in this age group | 5 to 17 | 18 to 37 | BMI < 50%ile | N/A | BMI ≥ 30 | 17% | | % OA who were OC | CDC / NCHS growth charts for 1963-94
FAIR
Guo et al 2002 ^17^ | 140 | 100% | 52% overall | 18 | 35 | ≥ 50th %ile | N/A | BMI ≥ 25 | 12.1 (5.49, 27.3) | 7.92 (3.61, 17.4) | RR or OR | CDC growth charts
FAIR | | | | | | | | | .69, sens/spec .83, .72 | .56, sens/spec .76, .73 | Other | NHANES I-III
BMI at 50th %ile
Guo et al 1994e ^9^ | 555 in whole cohort | 100% | 50% | 3 | 35 | BMI at the 50th %ile | N/A | BMI > 28 (m), > 26 (f) | 0.12 | 0.10 | Other | NHANES II
FAIR | | | | 8 | | | | | 0.11 | 0.08
| | | | 13 | | | | | 0.07 | 0.09
| | | | 18 | | | | | 0.06 | 0.07
BMI: 95th vs. 75th %ile
Guo et al 1994 ^9^ | 555 in whole cohort | 100% | 50% | 3 | 35 | At 95th vs at 75th %ile | N/A | BMI > 28 (m), > 26 (f) | 1.37 (0.99, 1.89) | 1.41 (1.00, 1.98) | RR or OR | NHANES II
FAIR | | | | 8 | | | | | 2.03 (1.39, 2.99) | 2.45 (1.54, 3.89)
| | | | 13 | | | | | 2.57 (1.76, 3.75) | 2.04 (1.41, 2.96)
| | | | 8 | | | | | 6.05 (3.03, 12.08) | 4.08 (2.34, 7.12)
BMI: 95th vs. 50th %ile
Guo et al 1994 ^9^ | 555 in whole cohort | 100% | 50% | 3 | 35 | At 95th vs at 50th %ile | N/A | BMI > 28 (m), > 26 (f) | 2.02 (0.98, 4.17) | 2.17 (1.01, 4.64) | RR or OR | NHANES II
FAIR | | | | 8 | | | | | 4.94 (2.08, 11.72) | 7.49 (2.64, 21.22)
| | | | 13 | | | | | 8.39 (3.59, 19.61) | 5.00 (2.17, 11.52)
| | | | 18 | | | | | 57.46 (12.15, 271.84) | 23.69 (6.78, 82.82)
BMI: 90th vs. 50th %ile
Lauer et al 1993 ^27^ | About 375 obs | 100% | N/A | 16 | 20 to 25 | QI %ile > 90 %ile vs ‘at the 50th %ile’ | N/A | QI %ile > 90 | 9 | 10 | RR or OR | age, sex, year specific %iles: study pop
FAIR | About 375 obs | 100% | N/A | 16 | 20 to 25 | QI %ile ‘at the 90 %ile’ vs ‘at the 50th %ile’ | N/A | QI %ile > 90 | 9 | 10 | RR or OR | age, sex, year specific %iles: study pop
BMI: 75th vs. 50th %ile
Guo et al 1994 ^9^ | 555 in whole cohort | 100% | 50% | 3 | 35 | At 75th vs at 50th | N/A | BMI > 28 (m), > 26 (f) | 1.48 (0.99, 2.21) | 1.54 (1.01, 2.35) | RR or OR | NHANES II
FAIR | | | | 8 | | | | | 2.43 (1.50, 3.92) | 3.06 (1.72, 5.46)
| | | | 13 | | | | | 3.26 (2.03, 5.23) | 2.44 (1.54, 3.89)
| | | | 8 | | | | | 9.49 (4.00, 22.51) | 5.80 (2.90, 11.63)
BMI: specific values
Valdez et al 1996 ^23^ | 148 | 100% black | 100% | 10 | 30 | BMI > 17 kg/m^2^ | N/A | BMI > 27 | - | 50% | % OC who became OA | N/A
FAIR | 302 | 100% | | | | BMI > 20 kg/m^2^ | | | - | 50%
| 121 | 100% black | 0% | | | BMI > 18 kg/m^2^ | | | 50% | -
| 264 | 100% | | | | BMI > 18 kg/m^2^ | | | 50% | -
| 148 | 100% black | 100% | 15 | 30 | BMI > 23 kg/m^2^ | | | - | 50%
| 302 | 100% | | | | BMI > 25 kg/m^2^ | | | - | 50%
| 121 | 100% black | 0% | | | BMI > 22 kg/m^2^ | | | 50% | -
| 264 | 100% | | | | BMI > 22 kg/m^2^ | | | 50% | -
W/H^3^ (aka Rohrer Index, Ponderal Index)
Freedman et al 1987i ^18^ | 1490 | 59% | 52% | 2 to 14 | 10 to 24 | RI: kg/m^3^ | Mean at baseline: 13.1 kg/m^3^ | RI: kg/m^3^ | 0.67 (.64, .70) | | Correlation | N/A
FAIR | 440 | 100% | 0% | | | | | | 0.70 (.65, .74)
| 432 | 100% | 100% | | | | | | | 0.57 (.50, .63)
| 281 | 100% black | 0% | | | | | | 0.72 (.66, .77)
| 337 | 100% black | 100% | | | | | | | 0.72 (.66, .77)
Freedman et al 2004 ^4^ | 885 | 67% overall; NR for this age group | 62% | 3 to 7 | 18 to 37 | W/H^3^ | NR: mean BMI for study pop is 17.7+/-3.4 | BMI (continuous) | 0.49 | 0.45 | Correlation | N/A
FAIR | | | | | | | | TSF + SSF sum | 0.38 | 0.34
| 2444 | | 56% | 8 to 13 | 18 to 37 | | | BMI (continuous) | 0.62 | 0.61
| | | | | | | | TSF + SSF sum | 0.48 | 0.46
Freedman et al 1987 ^18^ | 255 | 59% overall | 52% overall | 9 to 10 | 18 to 19 | RI: kg/m^3^ | NR by groups | RI: kg/m^3^ | 0.76 (.70, .81) | | Correlation | N/A
FAIR
Webber et al 1986 ^28^ | 42 | NR: 67% in other BHS | NR: 57% in other BHS | 10 to 11 | 17 to 18 | PI: W/H^3^ | Mean PI at baseline ranged from 11.0 +/- 0.5 to 13.3 +/- 2.1 (m), from 11.6 +/- 1.2 to 16.4 +/- 2.9 (f); varied by age and race; T 1–2 | PI: W/H^3^ | 0.93 | 0.73 | Correlation | N/A
FAIR
Valdez et al 1996j ^23^ | 835 | 68% | 54% | 10 to 15 | 25 to 30 | PI | Mean 12.5 +/- 0.13 (wm); 12.1 +/- 0.19 (bm); 12.4 +/- 0.12 (wf); 12.7 +/-0.17 (bf) | BMI > 27 | 0.64 | | Correlation | N/A
FAIR | | | | | | | | | 2.18 (1.82 – 2.61) | 2.04 (1.75 – 2.38) | RR or OR
Freedman et al 1987 ^18^ | 288 | 59% overall | 52% overall | 11 to 14 | 20 to 24 | RI: kg/m^3^ | NR by groups | RI: kg/m^3^ | 0.72 (.66, .77) | | Correlation | N/A
FAIR | 57 | 100% black | 100% | | | | | | | 0.83 (.73, .90)
Webber et al 1986 ^28^ | 162 | NR: 67% in other BHS | NR: 57% in other BHS | 12 to 13 | 19 to 20 | PI: W/H^3^ | Mean PI at baseline ranged from 11.0 +/- 0.5 to 13.3 +/- 2.1 (m), from 11.6 +/- 1.2 to 16.4 +/- 2.9 (f); varied by age and race; T 1–2 | PI: W/H^3^ | 0.82 | 0.82 | Correlation | N/A
FAIR | 80 | NR: 67% in other BHS | NR: 57% in other BHS | 14 to 15 | 21 to 22 | PI: W/H^3^ | Mean PI at baseline ranged from 11.0 +/- 0.5 to 13.3 +/- 2.1 (m), from 11.6 +/- 1.2 to 16.4 +/- 2.9 (f); varied by age and race; T 1–2 | PI: W/H^3^ | 0.7 | 0.91 | Correlation | N/A
Freedman et al 2004 ^4^ | 2212 | 67% overall; NR for this age group | 56% | 14 to 17 | 18 to 37 | W/H^3^ (assume kg/m^3^) | NR: mean BMI for study pop is17.7+/-3.4 | BMI (continuous) | 0.73 | 0.72 | Correlation | N/A
FAIR | | | | | | | | TSF + SSF sum | 0.53 | 0.54
W/H^3^ > 95 %ile
Freedman et al 1987 ^18^ | 74 | 59% overall | 52% overall | 2 to 14 | 10 to 24 | RI > 95th %ile: kg/m^3^ | N/A | RI > 95th %ile: kg/m^3^ | 72% | | % OC who became OA | in-study
FAIR
W/H^3^ > 85 %ile
Freedman et al 1987 ^18^ | 1490 | 59% | 52% | 2 to 14 | 10 to 24 | RI > 85th %ile: kg/m^3^ | N/A | RI > 85th %ile: kg/m^3^ | 50% | | % OC who became OA | in-study
FAIR
W/H^3^ specific values
Valdez et al 1996 ^23^ | 148 | 100% black | 100% | 10 | 30 | PI > 12 kg/m^3^ | N/A | BMI > 27 | - | 50% | % OC who became OA | N/A
FAIR | 302 | 100% | 100% | | | PI >14 kg/m^3^ | | | - | 50%
| 121 | 100% black | 0% | | | PI > 13 kg/m^3^ | | | 50% | -
| 264 | 100% | 0% | | | PI > 13 kg/m^3^ | | | 50% | -
| 148 | 100% black | 100% | 15 | 30 | PI > 14 kg/m^3^ | | | - | 50%
| 302 | 100% | 100% | | | PI > 16 kg/m^3^ | | | - | 50%
| 121 | 100% black | 0% | | | PI > 13 kg/m^3^ | | | 50% | -
| 264 | 100% | 0% | | | PI > 13 kg/m^3^ | | | 50% | -
Triceps Skinfold
Freedman et al 1987 ^18^ | 1490 | 59% | 52% | 2 to 14 | 10 to 24 | TSF | 12 mm NR for groups | TSF | 0.54 (.50, .57) | | Correlation | N/A
FAIR | 440 | 100% | 0% | | | | | | 0.52 (.45, .59)
| 432 | 100% | 100% | | | | | | | 0.45 (.37, .52)
| 281 | 100% black | 0% | | | | | | 0.59 (.51, .66)
| 337 | 100% black | 100% | | | | | | | 0.64 (.57, .70)
Clarke and Lauer 1993c ^22^ | 1286 obs | 100% | 53% | 9 to 10 | 21 to 25 | TSF | Baseline NR | TSF | 0.49 | 0.44 | Correlation | N/A
FAIR | 304 obs | | 58% | | 26 to 30 | | | | 0.58 | 0.50
Freedman et al 1987 ^18^ | 255 | 59% overall | 52% overall | 9 to 10 | 18 to 19 | TRSF | NR for groups | TSF | 0.56 (.47, .64) | | Correlation | N/A
FAIR
Lauer et al 1997 ^8^ | 2631 | 100% | NR probably around 50 | 9 to 18 | 23 to 33 | TSF | NR | TSF | .26 – .58 | | Correlation | N/A
FAIR
Webber et al 1986a ^28^ | 359 | 64% overall | 48% overall | 11 to 12 | 17 to 18 | TSF | Baseline mean TSF range: 10 +/- 3 mm – 17+/-7 mm; varies by age, study yr at baseline | TSF | 0.88 | | Correlation | N/A
FAIR
Freedman et al 1987 ^18^ | 288 | 59% overall | 52% overall | 11 to 14 | 20 to 24 | TRSF | NR for groups | TRSF | 0.57 (.49, .64) | | Correlation | N/A
FAIR | 57 | 100% black | 100% | | 10 to 24 | | | | | 0.65 (.47, .78)
Clarke and Lauer 1993c ^22^ | 1104 obs | 100% | 54% | 13 to 14 | 21 to 25 | TSF | baseline NR | TSF | 0.45 | 0.49 | Correlation | N/A
FAIR | 713 obs | | 56% | | 26 to 30 | | | | 0.48 | 0.48
| 104 obs | | 52% | | 31 tp 35 | | | | 0.72 | 0.55
Webber et al 1986a ^28^ | 188 | 64% overall | 48% overall | 13 to 14 | 17 to 18 | TSF | Baseline mean TSF range: 10 +/- 3 mm – 17+/-7 mm; varies by age, study yr at baseline | TSF | 0.77 | | Correlation | N/A
FAIR | | | | | 19 to 20 | | | | 0.92
Clarke and Lauer 1993c ^22^ | 631 obs | 100% | 52% | 17 to 18 | 21 to 25 | TSF | Baseline NR | TSF | 0.43 | 0.5 | Correlation | N/A
FAIR | 676 obs | | 52% | | 26 to 30 | | | | 0.44 | 0.49
| 218 obs | | 51% | | 31 to 35 | | | | 0.26 | 0.53
Webber et al 1986b ^28^ | 3051 | 64% overall | 48% overall | 10 to 15 | 15 to 20 | TSF | Baseline mean TSF range: 10 +/- 3 mm – 17+/-7 mm; varies by age, study yr at baseline | TSF | about .65 | | | N/A
FAIR
Triceps Skinfold: > 95th %ile
Freedman et al 1987 ^18^ | 74 | 59% overall | 52% overall | 2 to 14 | 10 to 24 | TSF > 95th %ile | N/A | TSF > 95th %ile | 66% | | % OC who became OA | in-study
FAIR
Triceps Skinfold 86th–95th %ile
Freedman et al 1987 ^18^ | 148 | 59% overall | 52% overall | 2 to 14 | 10 to 24 | TSF 86–95th%ile | N/A | TSF 86–95th%ile | 32% | | % OC who became OA | in-study
FAIR
Triceps Skinfold ≥ 85th %ile
Garn and Lavelle 1985 ^7^ | 383 | 100% | 56% | 0.5 to 5.5 | 21 to 25 | TSF ≥ 85th %ile | N/A | TSF ≥ 85th %ile | 0.11 | 0.15 | Correlation | Met Life Ins tables 1960
FAIR | | | | | | | | | 1.73 | | RR or OR
| | | | | | | | | 26% | | % OC who became OA
Freedman et al 1987 ^18^ | 1490 | 59% | 52% | 2 to 14 | 10 to 24 | TSF > 85th %ile | N/A | TSF > 85th %ile | 43% | | % OC who became OA | in-study
FAIR | | | | | | | | | 43% | | % OA who were OC
| 63 | 100% | 100% | | | | | | - | 35% | % OC who became OA
Garn and Lavelle 1985 ^7^ | 79 | 100% | 56% | 5 | 25 | TSF ≥ 85th %ile | N/A | TSF ≥ 85th %ile | 0.35 | 0.18 | Correlation | Met Life Ins tables 1960
FAIR | | | | | | | | | 0.87 | | RR or OR
| | | | | | | | | 13% | | % OC who became OA
Freedman et al 1987 ^18^ | 223 | 59% whole cohort | 52% whole cohort | 11 to 14 | 10 to 24 | TSF > 85th %ile | N/A | TSF > 85th %ile | 59% | | % OC who became OA | in-study
FAIR
Triceps Skinfold ≥ 80th %ile
Clarke and Lauer 1993c ^22^ | 1286 obs | 100% | 53% | 9 to 10 | 21 to 25 | TSF top quintile | N/A | TSF top quintile | 46% | 45% | % OC who became OA | Muscatine study population
FAIR | 304 obs | | 58% | | 26 to 30 | | | | 45% | 40%
| 1104 obs | | 54% | 13 to 14 | 21 to 25 | | | | 44% | 50%
| 713 obs | | 56% | | 26 to 30 | | | | 51% | 42%
| 104 obs | | 52% | | 31 to 35 | | | | 57% | 25%
| 631 obs | | 52% | 17 to 18 | 21 to 25 | | | | 44% | 50%
| 676 obs | | 52% | | 26 to 30 | | | | 52% | 47%
| 218 obs | | 51% | | 31 to 35 | | | | 42% | 42%
Lauer et al 1997 ^8^ | 2631 | 100% | NR, probably around 50 | 9 to 18 | 23 to 33 | Highest TSF quintile | N/A | Highest TSF quintile | 25–56% | | % OC who became OA | NHANES II
FAIR
Other measures: SSF
Freedman et al 1987 ^18^ | 1490 | 59% overall | 52% overall | 7 to 19 | 10 to 24 | SSF | N/A | SSF | 0.8 | | Correlation | N/A
FAIR
Garn and Lavelle 1985 ^7^ | 79 | 100% | 56% | 5 | 25 | SSF ≥ 85th %ile | N/A | SSF ≥ 85th %ile | 0.22 | 0.13 | Correlation | Met Life Ins tables 1960
FAIR | | | | | | | | | 0.80 | | RR or OR
| | | | | | | | | 25.0% | | % OC who became OA
| 383 | | | 0.5 to 5.5 | 21 to 25 | | | | 0.13 | 0.20 | Correlation
| | | | | | | | | 1.77 | | RR or OR
| | | | | | | | | 27.1% | | % OC who became OA
Freedman et al 1987 ^18^ | 195 | 59% overall | 52% overall | 11 to 14 | 10 to 24 | SSF > 85th %ile | N/A | SSF > 85th %ile | 70% | | % OC who became OA | in-study
FAIR

Notes to this table:

a Data also available for youth measurements at early adolescence (2 yr before yr of peak height velocity), yr of peak ht velocity, and 2 yr after yr of peak velocity; this table includes info on ages 5–7, 18).

b Estimated from bar graph.

c The number of children measured at baseline is not given, but rather the number of observations in that age group.

d Black females 3.4x more likely to become OA as white females of same BMI, age.

e Statistics represent probability of OW at 35.

f These data are for children for whom parental data available: controlling for parents' obesity status.

g 7% of normal weight children became OA.

h 17% of OW adults were normal weight children.

i Tracking differs by Tanner stage at baseline.

j Black females 3.8x more likely to become OA as white females with same BMI, age.

### References for Appendix J

1 Reilly JJ, Methven E, McDowell ZC, Hacking B, Alexander D, Stewart L, et al. Health consequences of obesity. Arch Dis Child. 2003;88(9):748-752. [pmid: 12937090]. [pmcid: 1719633].
2 Serdula MK, Ivery D, Coates RJ, Freedman DS, Williamson DF, Byers T. Do obese children become obese adults? A review of the literature. Prev Med. 1993;22(2):167-177. [pmid: 8483856].
3 Power C, Lake JK, Cole TJ. Measurement and long-term health risks of child and adolescent fatness. Int J Obes Relat Metab Disord. 1997;21(7):507-526. [pmid: 9226480].
4 Freedman DS, Khan LK, Serdula MK, Dietz WH, Srinivasan SR, Berenson GS. Inter-relationships among childhood BMI, childhood height, and adult obesity: the Bogalusa Heart Study. International Journal of Obesity & Related Metabolic Disorders. 2004;28(1):10-16. [pmid: 14652621].
5 Hulman S, Kushner H, Katz S, Falkner B. Can cardiovascular risk be predicted by newborn, childhood, and adolescent body size? An examination of longitudinal data in urban African Americans. Journal of Pediatrics. 1998;132(1):90-97. [pmid: 9470007].
6 Wattigney WA, Webber LS, Srinivasan SR, Berenson GS. The emergence of clinically abnormal levels of cardiovascular disease risk factor variables among young adults: the Bogalusa Heart Study. Preventive Medicine. 1995;24(6):617-626. [pmid: 8610086].
7 Garn SM, Lavelle M. Two-decade follow-up of fatness in early childhood. Am J Dis Child. 1985;139(2):181-185. [pmid: 3976591].
8 Lauer RM, Clarke WR, Burns TL. Obesity in childhood: the Muscatine Study. Chung-Hua Min Kuo Hsiao Erh Ko i Hsueh Hui Tsa Chih. 1997;38(6):432-437. [pmid: 9473814].
9 Guo SS, Roche AF, Chumlea WC, Gardner JD, Siervogel RM. The predictive value of childhood body mass index values for overweight at age 35 y. American Journal of Clinical Nutrition. 1994;59(4):810-819. [pmid: 8147324].
10 Whitaker RC, Wright JA, Pepe MS, Seidel KD, Dietz WH. Predicting obesity in young adulthood from childhood and parental obesity. N Engl J Med. 1997;337(13):869-873. [pmid: 9302300].
11 Dietz WH. Health consequences of obesity in youth: childhood predictors of adult disease. Pediatrics. 1998;101(3 Pt 2):518-525. [pmid: 12224658].
12 Whitaker RC, Pepe MS, Wright JA, Seidel KD, Dietz WH. Early adiposity rebound and the risk of adult obesity. Pediatrics. 1998;101(3):E5. [pmid: 9481024].
13 Siervogel RM, Roche AF, Guo SM, Mukherjee D, Chumlea WC. Patterns of change in weight/stature2 from 2 to 18 years: findings from long-term serial data for children in the Fels longitudinal growth study. Int J Obes. 1991;15(7):479-485. [pmid: 1845371].
14 Wisemandle W, Maynard LM, Guo SS, Siervogel RM. Childhood weight, stature, and body mass index among never overweight, early-onset overweight, and late-onset overweight groups. Pediatrics. 2000;106(1):E14. [pmid: 10878143].
15 Kuczmarski RJ, Ogden CL, Guo SS, Grummer-Strawn LM, Flegal KM, Mei Z et al. 2000 CDC Growth Charts for the United States: methods and development. Vital Health Stat 11 2002;(246):1–190.
16 Freedman DS, Khan LK, Dietz WH, Srinivasan SR, Berenson GS. Relationship of childhood obesity to coronary heart disease risk factors in adulthood: the Bogalusa Heart Study. Pediatrics. 2001;108(3):712-718. [pmid: 11533341].
17 Guo SS, Wu W, Chumlea WC, Roche AF. Predicting overweight and obesity in adulthood from body mass index values in childhood and adolescence.[comment]. American Journal of Clinical Nutrition. 2002;76(3):653-658. [pmid: 12198014].
18 Freedman DS, Shear CL, Burke GL, Srinivasan SR, Webber LS, Harsha DW, et al. Persistence of juvenile-onset obesity over eight years: the Bogalusa Heart Study. American Journal of Public Health. 1987;77(5):588-592. [pmid: 3565653]. [pmcid: 1647043].
19 Casey VA, Dwyer JT, Coleman KA, Valadian I. Body mass index from childhood to middle age: a 50-y follow-up. Am J Clin Nutr. 1992;56(1):14-18. [pmid: 1609751].
20 Lauer RM, Lee J, Clarke WR. Factors affecting the relationship between childhood and adult cholesterol levels: the Muscatine Study. Pediatrics. 1988;82(3):309-318. [pmid: 3405659].
21 Lauer RM, Clarke WR. Childhood risk factors for high adult blood pressure: the Muscatine Study. Pediatrics. 1989;84(4):633-641. [pmid: 2780125].
22 Clarke WR, Lauer RM. Does childhood obesity track into adulthood?. Crit Rev Food Sci Nutr. 1993;33(45):423-430. [pmid: 8357505].
23 Valdez R, Greenlund KJ, Wattigney WA, Bao W, Berenson GS. Use of weight-for-height indices in children to predict adult overweight: the Bogalusa Heart Study. International Journal of Obesity & Related Metabolic Disorders. 1996;20(8):715-721. [pmid: 8856393].
24 Sinaiko AR, Donahue RP, Jacobs DR Jr., Prineas RJ. Relation of weight and rate of increase in weight during childhood and adolescence to body size, blood pressure, fasting insulin, and lipids in young adults. The Minneapolis Children's Blood Pressure Study. Circulation. 1999;99(11):1471-1476. [pmid: 10086972].
25 Gortmaker SL, Must A, Perrin JM, Sobol AM, Dietz WH. Social and economic consequences of overweight in adolescence and young adulthood. New England Journal of Medicine. 1993;329(14):1008-1012. [pmid: 8366901].
26 Srinivasan SR, Bao W, Wattigney WA, Berenson GS. Adolescent overweight is associated with adult overweight and related multiple cardiovascular risk factors: the Bogalusa Heart Study. Metabolism: Clinical & Experimental. 1996;45(2):235-240. [pmid: 8596496].
27 Lauer RM, Clarke WR, Mahoney LT, Witt J. Childhood predictors for high adult blood pressure. The Muscatine Study. Pediatric Clinics of North America. 1993;40(1):23-40. [pmid: 8417407].
28 Webber LS, Cresanta JL, Croft JB, Srinivasan SR, Berenson GS. Transitions of cardiovascular risk from adolescence to young adulthood—the Bogalusa Heart Study: II. Alterations in anthropometric blood pressure and serum lipoprotein variables. Journal of Chronic Diseases. 1986;39(2):91-103. [pmid: 3944231].