# Appendix A. Abbreviations

Abbreviation | Definition
AHRQ | Agency for Healthcare Research and Quality
AR | adiposity rebound
b or B | black
BCI | behavioral counseling interventions
BHS | Bogalusa Heart Study
BIA | bioelectrical impedance analysis
BMC | bone mineral content
BMI | body mass index
BP | blood pressure
bpm | beats per minute
BT | behavioral therapy
CCT | controlled clinical trial
CDC | Centers for Disease Control and Prevention
CHD | coronary heart disease
CHO | carbohydrate
CI or C.I. | confidence interval
cm | centimeter(s)
comp | comparison intervention
cont | control group
CT | computed tomography
CTF | Community Task Force
CV | cardiovascular
CVD | cardiovascular disease
DBP | diastolic blood pressure
DEXA | dual energy X-ray absorptiometry
DM | diabetes mellitus
DMII | diabetes mellitus II
ECG | electrocardiogram
Exp | experimental intervention
f or F | female
FFM | fat-free mass
FM | fat mass
f/u | follow up
g | gram(s)
GBD | gallbladder disease
GTT | glucose tolerance test
H | height or Hispanic
HDL | high-density lipoprotein
HDLC | high-density lipoprotein cholesterol
HH | healthy habits
HHANES | Hispanic Health and Nutrition Examination Survey
HIPT | high-intensity physical activity treatment
HMO | health maintenance organization
HOMA | homeostatic model of insulin sensitivity
HR | hazards ratio or heart rate
ht or Ht | height
IBW | ideal body weight
in | inches
int | intervention
IOTF | International Obesity Task Force
kcal | kilocalorie(s)
kcal/d | kilocalorie(s)/day
kg | kilogram(s)
kg/m^2^ | kilograms divided by meters squared
KQ | Key Question
lbs | pounds
LDL | low-density lipoprotein
LSE | lifestyle education
m or M | male
MA | Mexican American
med | medium
METS | metabolic equivalents
mg | milligram(s)
mg/dL | milligram(s)/deciliter
mi | mile(s)
min | minute(s)
MIPT | medium-intensity physical activity treatment
mL | milliliter(s)
mm | millimeter(s)
mmHg | millimeters of mercury
mo(s) | month(s)
mod | moderate
MRI | magnetic resonance imaging
n or N | number
NA | Native American
N/A | not applicable or not available
NAA | neutron activation analysis
NASH | non-alcoholic steatohepatitis
NCHS | National Center for Health Statistics
NHANES | National Health and Nutrition Examination Survey
NHB | non-Hispanic black
NHES | National Health Examination Survey
NHW | non-Hispanic white
NIH | National Institutes of Health
NNS | number needed to screen
NNT | number needed to treat
NR | not reported
NS or n.s. | not significant
OA | osteoarthritis or overweight adults
obs | observations
OC | overweight children
O:E | observed: expected
OR | odds ratio
OW | overweight
p | p value
PA | physical activity
PC | phone call
PCP | primary care provider
PI | ponderal index (w/h^3^)—same measure as Rohrer index
pop | population
Prev | prevalence
Prob | probability
PS | problem solving
pts | patients
QD | every day
QI | Quetelet index (w/h^2^)
r | regression coefficient
RCT | randomized clinical trial
RF | reduced fat
RGL | reduced glycemic load
RI | Rohrer index (w/h^3^)
ROC | receiver-operating characteristic
RR | relative risk
SA | sleep apnea
SB | sedentary behavior
SBP | systolic blood pressure
SD | standard deviation
SE | standard error
sens | sensitivity
SKF | skinfold thickness
spec | specificity
SSF | subscapular skinfold thickness
TBW | total body weight
TC | total cholesterol or typical care
TG | triglycerides
TLD | Traffic Light Diet
TOBEC | total body electrical conductivity
TSF | triceps skinfold
UK | United Kingdom
US | United States or ultrasound
USPSTF | U.S. Preventive Services Task Force
VLDL | very low density lipoprotein
VO2 | volume of oxygen
w or W | white
W/H | weight for height
WHO | World Health Organization
wk | week(s)
WLBS | Weight Loss Behavior Scale
wm | white male
wt | weight
yo | years old
yr | year(s)