# Appendixes

Appendix A. Abbreviations

Appendix B. Measuring Adiposity in Children and Adolescents

Appendix C. Clinical Measures of Overweight

Appendix D. Search Strategies

Appendix E. Previously Conducted Systematic Evidence Reviews of Interventions for Childhood Overweight

Appendix F. Inclusion Criteria and Results of Searches

Appendix G. Exclusion Table for Key Questions 2b and 2c

Appendix H. Exclusion Table for Key Questions 4 and 5

Appendix I. USPSTF Hierarchy of Research Design and Quality Rating Criteria

Appendix J. Childhood Overweight Clinical Screening Tests and Predicting Adult Obesity

Appendix K. Childhood Overweight Clinical Screening Tests to Predict Poorer Health Outcomes

Appendix L. Evidence Table: Intervention Trials 2001-Present

Appendix M. Evidence Table: Intervention Study Characteristics

Appendix N. Screening and Intervention for Overweight in Children and Adolescents Categorization Scheme for Settings

Appendix O. Intervention Characteristic Definitions

Appendix P. Methods for and

Appendix Q. Outcomes Table Modeling Potentially Prevented Adult Cases of Disease by Screening 1,000 Adolescents and Treating Overweight Adolescents ( ≥95^th^ Percentile)

Appendix R. Population-Based Obesity Prevalence Surveys

Appendix S. Expert Reviewers