# Appendix D. USPSTF Quality Rating Criteria and Hierarchy of Research Design^1,^ ^2^

## Design-Specific Criteria and Quality Category Definitions

### Systematic Reviews

Criteria:

- Comprehensiveness of sources considered/search strategy used.
- Standard appraisal of included studies.
- Validity of conclusions.
- Recency and relevance are especially important for systematic reviews.

Definition of ratings from above criteria:

Good: Recent, relevant review with comprehensive sources and search strategies; explicit and relevant selection criteria; standard appraisal of included studies; and valid conclusions.

Fair: Recent, relevant review that is not clearly biased but lacks comprehensive sources and search strategies.

Poor: Outdated, irrelevant, or biased review without systematic search for studies, explicit selection criteria, or standard appraisal of studies.

### Case-Control Studies

Criteria:

- Accurate ascertainment of cases.
- Nonbiased selection of cases/controls with exclusion criteria applied equally to both.
- Response rate.
- Diagnostic testing procedures applied equally to each group.
- Measurement of exposure accurate and applied equally to each group.
- Measurement of exposure accurate and applied equally to each group.
- Appropriate attention to potential confounding variables.

Definition of ratings based on criteria above:

Good: Appropriate ascertainment of cases and nonbiased selection of case and control participants; exclusion criteria applied equally to cases and controls; respo9nse rate equally to or greater than 80 percent; diagnostic procedures and measurements accurate and applied equally to cases and controls; and appropriate attention to confounding variables.

Fair: Recent, relevant, without major apparent selection or diagnostic work-up bias but with response rates less than 80 percent or attention to some but not all important confounding variables.

Poor: Major section or diagnostic work-up biases, response rates less than 50 percent, or inattention to confounding variables.

### Randomized Controlled Trials and Cohort Studies

Criteria:

- Initial assembly of comparable groups:
  - -for randomized controlled trials (RCTs): adequate randomization, including first concealment and whether potential confounders were distributed equally among groups.
  - -for cohort studies: consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts.
- Maintenance of comparable groups (includes attrition, cross-overs, adherence, contamination).
- Important differential loss to follow-up or overall high loss to follow-up.
- Measurements: equal, reliable, and valid (includes masking of outcome assessment).
- Clear definition of the interventions.
- All important outcomes considered.

Definition of ratings based on above criteria:

Good: Evaluates relevant available screening tests; uses a credible reference standard; interprets reference standard independently of screening test; reliability of test assessed; has few or handles indeterminate results in a reasonable manner; includes large number (more than 100 broad-spectrum of patients.

Fair: Evaluates relevant available screening tests; uses reasonable although not best standard; interprets reference standard independent of screening test; moderate sample size (50 to 100 subjects) and a “medium” spectrum of patients.

Poor: Has fatal flaw such as: Uses inappropriate reference standard; screening test improperly administered; biased ascertainment of reference standard; very small sample size or very narrow selected spectrum of patients.

### Diagnostic Accuracy Studies

Criteria:

- Screening test relevant, available for primacy care, adequately described.
- Study uses a credible reference standard, performed regardless of test results.
- Reference standard interpreted independently of screening test.
- Handles indeterminate result in a reasonable manner.
- Spectrum of patients included in study.
- Sample size.
- Administration of reliable screening test.

Definition of ratings based on above criteria:

Good: Evaluates relevant available screening test; uses a credible reference standard; interprets reference standard independently of screening test; reliability of test assessed; has few or handles indeterminate results in a reasonable manner; includes large number (more than 100) broad-spectrum patients with and without disease.

Fair: Evaluates relevant available screening test; uses reasonable although not best standard; interprets reference standard independent of screening test; moderate sample size (50–100 subjects) and a “medium” spectrum of patients.

Poor: Has fatal flaw such as: Uses inappropriate reference standard; screening test improperly administered; biased ascertainment of reference standard; very small sample size or very narrow selected spectrum patients.

### Hierarchy of Research Design

I Properly conducted randomized controlled trial (RCT).

II-1: Well-designed controlled trial without randomization.

II-2: Well-designed cohort or case-control analytic study.

II-3: Multiple time series with or without the intervention; dramatic results from uncontrolled experiments.

III: Opinions of respected authorities, based on clinical experience; descriptive studies or case reports; reports of expert committees.

### Reference

#### References

Saha S, Hoerger T J, Pignone M P, Teutsch S M, Helfand M, Mandelblatt J S. Cost Work Group, Third U.S. Preventive Services Task Force. Am J Prev Med. 2001;20(3):36-43. [pmid: 11306230].
Harris R P, Helfand M, Woolf S H, Lohr K N, Mulrow C D, Teutsch S M, et al. Current methods of the US Preventive Services Task Force: a review of the process. American Journal of Preventive Medicine. 2001;20(3:Suppl):Suppl-35.