# Appendix C. Excluded Studies

Key Question 1a Does AAA screening, in an asymptomatic average-risk or high-risk population, reduce AAA-related adverse health outcomes?

Study | Reason for Exclusion
Heather BP, Poskitt KR, Earnshaw JJ, Whyman M, Shaw E. Population screening reduces mortality rate from aortic aneurysm in men. Br J Surg. 2000; 87(6):750–753. | Not a randomized controlled trial.
Wilmink TB, Quick CR, Hubbard C, Day NE. The influence of screening on the incidence of ruptured abdominal aortic aneurysms. J Vasc Surg. 1999;30(2):203–208. | Not a randomized controlled trial.