# Appendix B. Inclusion Criteria and Search Results

Key Question (KQ) | Inclusion Criteria | # Abstracts Reviewed* | # Articles Reviewed | Included Articles
KQ 1: a. Does AAA screening in an asymptomatic average-risk population reduce AAA-related adverse health outcomes? | Unselected population relevant to primary care, reported health outcome reduction of AAA specific morbidity/mortality/rupture rate, randomized controlled trial, USPSTF quality of fair or good, English. | 39 | 7 | 5
KQ 1: b. For individuals who do not have AAAs on initial screening, does periodic repeat screening reduce AAA-related adverse health outcomes? | Follow-up or cohort study that included repeat scanning of a representative population, USPSTF quality of fair or good, English. | 108 | 8 | 4
KQ 2: What are the harms associated with AAA screening? | RCT (or cohort study if no RCT available) screening for AAA, which explicitly evaluates or discusses harms, USPSTF quality of fair or good, English. | 32 | 4 | 4
KQ 3: For 3.0–5.5 cm AAAs detected through screening, does immediate repair or surveillance reduce AAA-specific adverse health outcomes? | Population relevant to primary care, reported AAA-specific adverse health outcome, randomized controlled trial, USPSTF quality of fair or good, English. | 387 | 5 | 2
KQ 4: What are the harms associated with repair of AAAs ≥ 5.5 cm? | RCT (or cohort study if no RCT available) of treatment of AAA, which explicitly evaluates or discusses harms, USPSTF quality of fair or good, English. | 92 | 8 | 6
KQ 5: What are the harms associated with immediate repair or surveillance of 3.0–5.4 cm AAAs? | | | 4 | 2

RCT, randomized controlled trial; USPSTF, U.S. Preventive Services Task Force

* All abstracts were reviewed for relevance to other key questions.