# Appendix A. Search Strategies

Databases: MEDLINE®, Cochrane database of systematic reviews, Cochrane central register of controlled trials.

Dates searched: 1994-2004

## Key Question 1a

1. controlled clinical trials
2. randomized controlled trials
3. multicenter studies
4. double-blind method
5. meta-analysis
6. random allocation
7. single-blind method
8. controlled clinical trial.pt
9. meta analysis.pt
10. randomized controlled trial.pt
11. (meta analy$ or metaanaly$).ti, ab
12. (systematic$ review$ or systematic$ overview$).ti,a b
13. (quantitative$ review$ or quantitative$ overview$).ti, ab
14. evidence based review$.ti, ab
15. or/1–14
16. aortic aneurysm, abdominal
17. 15 and 16
18. mass screening
19. screen$.ti, ab
20. 17 and (18 or 19)
21. limit 20 to yr=1994-2004
22. limit 21 to English language

## Key Question 1b

1. Epidemiologic studies/ Epidemiologic studies
2. exp cohort studies
3. Case control.tw
4. (cohort adj (study or studies)).tw
5. Cohort analy$.tw
6. (Follow up adj (study or studies)).tw
7. (observational adj (study or studies)).tw
8. Longitudinal.tw
9. Retrospective.tw
10. Cross sectional.tw
11. Cross-sectional studies
12. or/1–11
13. mass screening/ or screen$.ti,ab
14. 12 and 13
15. aortic aneurysm, abdominal
16. 14 and 15
17. limit 16 to (English language and yr=1994-2004)

## Key Question 2

1. Stress, psychological
2. Anxiety
3. (anxiety or anxious$).ti,ab.
4. Depression
5. Depressive disorder
6. depress$.ti,ab.
7. harm$.ti,ab.
8. adverse effect$.ti,ab.
9. *“Risk Assessment”
10. “Predictive Value of Tests”
11. “Attitude to Health”
12. “Psychiatric Status Rating Scales”
13. “Health Status”
14. *“Health Status Indicators”
15. “Severity of Illness Index”
16. “Quality of Life”
17. false positive reactions
18. false negative reactions
19. or/1–18
20. aortic aneurysm, abdominal
21. mass screening
22. screen$.ti,ab.
23. or/21–22
24. 20 and 23
25. 24 and 19
26. limit 25 to yr=1994-2004
27. limit 26 to (human and English language)

## Key Question 3

1. exp clinical trials/ or clinical trials.mp
2. controlled clinical trials/ or controlled clinical trials.mp
3. randomized controlled trials/ or randomized controlled trials.mp
4. multicenter studies/ or multicenter studies.mp
5. Double-Blind Method/ or double blind.mp
6. Single-Blind Method/ or Single Blind.mp
7. Meta-Analysis/ or Meta-Analysis.mp
8. Random Allocation/ or Random Allocation.mp
9. or/1–8
10. RANDOMIZED-CONTROLLED-TRIAL.pt
11. META-ANALYSIS.pt
12. CONTROLLED-CLINICAL-TRIAL.pt
13. CLINICAL-TRIAL.pt
14. or/10–13
15. (meta analy$ or metaanaly$).ti,ab
16. (systematic$ review$ or systematic$ overview$).ti,ab
17. evidence based review$.ti,ab
18. random$.ti,ab
19. ((doubl$ or singl$) and blind$).ti,ab
20. (meta-anal$ or metaanaly$ or meta analy$).ti,ab
21. or/15–20
22. 9 or 14 or 21
23. vascular surgical procedures
24. surgical procedures, elective
25. surgery
26. surg$.ti,ab
27. “open repair”.ti,ab
28. aortic aneurysm, abdominal/su
29. or/23–28
30. blood vessel prosthesis implantation
31. (endo$ or endovascular or pevr or evar).ti,ab
32. or/30–31
33. aortic aneurysm, abdominal
34. 29 or 32
35. 33 and 34 and 22
36. limit 35 to yr=1994-2004
37. limit 36 to (human and English language)

## Key Question 4 and 5

1. treatment outcome
2. cause of death
3. mortality
4. morbidity
5. postoperative complications
6. or/1–5
7. “Prognosis”
8. “Survival Rate”
9. “Survival Analysis”
10. “Risk Factors”
11. or/7–10
12. vascular surgical procedures
13. surgical procedures, elective
14. surgery
15. surg$.ti,ab
16. “open repair”.ti,ab
17. or/12–16
18. blood vessel prosthesis implantation
19. (endo$ or endovascular or pevr or evar).ti,ab
20. or/19–20
21. controlled clinical trials
22. randomized controlled trials
23. multicenter studies
24. Double-Blind Method
25. Meta-Analysis
26. Random Allocation
27. Single-Blind Method
28. controlled clinical trial.pt
29. meta analysis.pt
30. randomized controlled trial.pt
31. (meta analy$ or metaanaly$).ti,ab
32. (systematic$ review$ or systematic$ overview$).ti,ab
33. (quantitative$ review$ or quantitative$ overview$).ti,ab
34. evidence based review$.ti,ab
35. or/21–34
36. 6 or 11
37. 17 or 20
38. 35 and (36 and 37)
39. aortic aneurysm, abdominal
40. 38 and 39
41. limit 40 to yr=1994-2004
42. limit 41 to (human and English language)