# References

1 Johnston K W, Rutherford R B, Tilson M D, Shah D M, Hollier L, Stanley J C. Suggested standards for reporting on arterial aneurysms. Subcommittee on Reporting Standards for Arterial Aneurysms, Ad Hoc Committee on Reporting Standards, Society for Vascular Surgery and North American Chapter, International Society for Cardiovascular Surgery. Journal of Vascular Surgery. 1991;13(3):452-458. [pmid: 1999868].
2 National Center for Health Statistics. National Vital Statistics Report 2002. 2002;50(16):14.
3 Gillum R F. Epidemiology of aortic aneurysm in the United States. Journal of Clinical Epidemiology. 1995;48(11):1289-1298. [pmid: 7490591].
4 Adam D J, Mohan I V, Stuart W P, Bain M, Bradbury A W. Community and hospital outcome from ruptured abdominal aortic aneurysm within the catchment area of a regional vascular surgical service. Journal of Vascular Surgery. 1999;30(5):922-928. [pmid: 10550191].
5 Lederle F A. Screening for snipers: the burden of proof. Journal of Clinical Epidemiology. 1990;43(1):101-4. [pmid: 2319273].
6 Bengtsson H, Bergqvist D, Ekberg O, Janzon L. A population based screening of abdominal aortic aneurysms (AAA). European Journal of Vascular Surgery. 1991;5(1):53-57. [pmid: 2009986].
7 Smith F C, Grimshaw G M, Paterson I S, Shearman C P, Hamer J D. Ultrasonographic screening for abdominal aortic aneurysm in an urban community. British Journal of Surgery. 1993;80(11):1406-1409. [pmid: 8252350].
8 Morris G E, Hubbard C S, Quick C R. An abdominal aortic aneurysm screening programme for all males over the age of 50 years. European Journal of Vascular Surgery. 1994;8(2):156-160. [pmid: 8181607].
9 Simoni G, Pastorino C, Perrone R, Ardia A, Gianrossi R, Decian F, et al. Screening for abdominal aortic aneurysms and associated risk factors in a general population. European Journal of Vascular & Endovascular Surgery. 1995;10(2):207-210. [pmid: 7655973].
10 Lindholt J S, Henneberg E W, Fasting H, Juul S. Mass or high-risk screening for abdominal aortic aneurysm. British Journal of Surgery. 1997;84(1):40-42. [pmid: 9043447].
11 Ashton H A, Buxton M J, Day N E, Kim L G, Marteau T M, Scott R A, et al. The Multicentre Aneurysm Screening Study (MASS) into the effect of abdominal aortic aneurysm screening on mortality in men: a randomised controlled trial. Lancet. 2002;360(9345):1531-1539. [pmid: 12443589].
12 Norman P E, Jamrozik K, Lawrence-Brown M M, Dickinson J A. Western Australian randomized controlled trial of screening for abdominal aortic aneurysm. British Journal of Surgery. 2003;90(4):492.
13 Lederle F A, Johnson G R, Wilson S E, Chute E P, Hye R J, Makaroun M S, et al. The aneurysm detection and management study screening program: validation cohort and final results. Aneurysm Detection and Management Veterans Affairs Cooperative Study Investigators. Archives of Internal Medicine. 2000;160(10):1425-1430. [pmid: 10826454].
14 Scott R A, Bridgewater S G, Ashton H A. Randomized clinical trial of screening for abdominal aortic aneurysm in women. British Journal of Surgery. 2002;89(3):283-285. [pmid: 11872050].
15 Lederle F A, Johnson G R, Wilson S E, Chute E P, Littooy F N, Bandyk D, et al. Prevalence and associations of abdominal aortic aneurysm detected through screening. Aneurysm Detection and Management (ADAM) Veterans Affairs Cooperative Study Group. Ann Intern Med. 1997;126(6):441-449. [pmid: 9072929].
16 Scott R A, Vardulaki K A, Walker N M, Day N E, Duffy S W, Ashton H A. The long-term benefits of a single scan for abdominal aortic aneurysm (AAA) at age 65. European Journal of Vascular & Endovascular Surgery. 2001;21(6):535-540. [pmid: 11397028].
17 Wilmink A B, Quick C R. Epidemiology and potential for prevention of abdominal aortic aneurysm. Br J Surg. 1998;85(2):155-162. [pmid: 9501808].
18 Best V A, Price J F, Fowkes F G. Persistent increase in the incidence of abdominal aortic aneurysm in Scotland, 1981-2000. British Journal of Surgery. 2003;90(12):1510-5. [pmid: 14648729].
19 Reitsma J B, Pleumeekers H J, Hoes A W, Kleijnen J, de Groot R M, Jacobs M J, et al. Increasing incidence of aneurysms of the abdominal aorta in The Netherlands. European Journal of Vascular & Endovascular Surgery. 1996;12(4):446-51. [pmid: 8980435].
20 Drott C, Arfvidsson B, Ortenwall P, Lundholm K. Age-standardized incidence of ruptured aortic aneurysm in a defined Swedish population between 1952 and 1988: mortality rate and operative results. British Journal of Surgery. 1992;79(2):175-9. [pmid: 1555072].
21 Bown M J, Sutton A J, Bell P R, Sayers R D. A meta-analysis of 50 years of ruptured abdominal aortic aneurysm repair. British Journal of Surgery. 2002;89(6):714-730. [pmid: 12027981].
22 Ailawadi G, Eliason J L, Upchurch G R Jr. Current concepts in the pathogenesis of abdominal aortic aneurysm. Journal of Vascular Surgery. 2003;38(3):584-588. [pmid: 12947280].
23 Gillum R F. Trends in acute myocardial infarction and coronary heart disease death in the United States. Journal of the American College of Cardiology. 1994;23(6):1273-1277. [pmid: 8176083].
24 Gillum R F, Sempos C T. The end of the long-term decline in stroke mortality in the United States?. Stroke. 1997;28(8):1527-1529. [pmid: 9259744].
25 Lederle F A, Nelson D B, Joseph A M. Smokers' relative risk for aortic aneurysm compared with other smoking-related diseases: a systematic review. J Vasc Surg. 2003;38(2):329-334. [pmid: 12891116].
26 Nevitt M P, Ballard D J, Hallett J W Jr. Prognosis of abdominal aortic aneurysms. A population-based study. New England Journal of Medicine. 1989;321(15):1009-1014. [pmid: 2674715].
27 Glimaker H, Holmberg L, Elvin A, Nybacka O, Almgren B, Bjorck C G, et al. Natural history of patients with abdominal aortic aneurysm. European Journal of Vascular Surgery. 1991;5(2):125-130. [pmid: 2037082].
28 Lederle F A, Johnson G R, Wilson S E, Ballard D J, Jordan W D Jr, Blebea J, et al. Rupture rate of large abdominal aortic aneurysms in patients refusing or unfit for elective repair. JAMA. 2002;287(22):2968-2972. [pmid: 12052126].
29 Bernstein E F, Chan E L. Abdominal aortic aneurysm in high-risk patients. Outcome of selective management based on size and expansion rate. Annals of Surgery. 1984;200(3):255-263. [pmid: 6465980].
30 Cronenwett J L, Murphy T F, Zelenock G B, Whitehouse W M Jr, Lindenauer S M, Graham L M, et al. Actuarial analysis of variables associated with rupture of small abdominal aortic aneurysms. Surgery. 1985;98(3):472-483. [pmid: 3898453].
31 Lederle F A, Wilson S E, Johnson G R, Reinke D B, Littooy F N, Acher C W, et al. Immediate repair compared with surveillance of small abdominal aortic aneurysms. New England Journal of Medicine. 2002;346(19):1437-1444. [pmid: 12000813].
32 United Kingdom Small Aneurysm Trial Participants. Mortality results for randomised controlled trial of early elective surgery or ultrasonographic surveillance for small abdominal aortic aneurysms. Lancet. 1998;352(9141):1649-1655. [pmid: 9853436].
33 Law M R, Morris J, Wald N J. Screening for abdominal aortic aneurysms. Journal of Medical Screening. 1994;1(2):110-115. [pmid: 8790498].
34 van der Vliet J A, Oomen A P. [Abdominal aortic aneurysm: screening and treatment]. Nederlands Tijdschrift voor Geneeskunde. 1993;137(23):1155. [pmid: 8316312].
Guide to Clinical Preventive Services. Report of the U.S. Preventive Services Task Force. 2nd ed. ed. Baltimore: Williams & Wilkins, 1996.
36 Norman P.E., Jamrozik K., Lawrence-Brown M.M., Le M.T.Q, Spencer CA, Tuohy RJ et al. Population based randomised controlled trial on impact of screening on mortality from abdominal aortic aneurysm. BMJ 2004.
37 Lindholt J S, Juul S, Fasting H, Henneberg E W. Hospital costs and benefits of screening for abdominal aortic aneurysms. Results from a randomised population screening trial. European Journal of Vascular & Endovascular Surgery. 2002;23(1):55-60. [pmid: 11748949].
38 Fink H A, Lederle F A, Roth C S, Bowles C A, Nelson D B, Haas M A. The accuracy of physical examination to detect abdominal aortic aneurysm. Archives of Internal Medicine. 2000;160(6):833-836. [pmid: 10737283].
39 Lederle F A, Walker J M, Reinke D B. Selective screening for abdominal aortic aneurysms with physical examination and ultrasound. Archives of Internal Medicine. 1988;148(8):1753-1756. [pmid: 3041938].
40 Harris R P, Helfand M, Woolf S H, Lohr K N, Mulrow C D, Teutsch S M, et al. Current methods of the US Preventive Services Task Force: a review of the process. American Journal of Preventive Medicine. 2001;20(3:Suppl):Suppl-35.
41 DerSimonian R, Laird N. Meta-analysis in clinical trials. Controlled Clinical Trials. 1986;7:177-188. [pmid: 3802833].
42 Normand S L. Meta-analysis: formulating, evaluating, combining, and reporting. Statistics in Medicine. 1999;18(3):321-59. [pmid: 10070677].
43 Reviewer Manager Version 4.2.2. (RevMan). Oxford, England: The Cochrane Collaboration, 2003.
44 Scott R A, Wilson N M, Ashton H A, Kay D N. Influence of screening on the incidence of ruptured abdominal aortic aneurysm: 5-year results of a randomized controlled study. British Journal of Surgery. 1995;82(8):1066-1070. [pmid: 7648155].
45 Vardulaki K A, Walker N M, Couto E, Day N E, Thompson S G, Ashton H A, et al. Late results concerning feasibility and compliance from a randomized trial of ultrasonographic screening for abdominal aortic aneurysm. British Journal of Surgery. 2002;89(7):861-864. [pmid: 12081734].
46 Jamrozik K, Norman P E, Spencer C A, Parsons R W, Tuohy R, Lawrence-Brown M M, et al. Screening for abdominal aortic aneurysm: lessons from a population-based study. Medical Journal of Australia. 2000;173(7):345-350. [pmid: 11062788].
47 Feinstein AR. Heterodemic Studies. Clinical epidemiology: the architecture of clinical research. Philadelphia: W.B. Saunders Company, 1985: 561.
48 Kim L G, Thompson S G, Marteau T M, Scott R A. Multicentre Aneurysm Screening Study Group. Screening for abdominal aortic aneurysms: the effects of age and social deprivation on screening uptake, prevalence and attendance at follow-up in the MASS trial. Journal of Medical Screening. 2004;11(1):50-3. [pmid: 15006116].
49 Lindholt J S, Juul S, Henneberg E W, Fasting H. Is screening for abdominal aortic aneurysm acceptable to the population? Selection and recruitment to hospital-based mass screening for abdominal aortic aneurysm. Journal of Public Health Medicine. 1998;20(2):211-217. [pmid: 9675742].
50 Humphrey L L, Helfand M, Chan B K, Woolf S H. Breast cancer screening: a summary of the evidence for the U.S. Preventive Services Task Force. Annals of Internal Medicine. 2002;137(5 Part 1):347-60. [pmid: 12204020].
51 Pignone M, Rich M, Teutsch S M, Berg A O, Lohr K N. Screening for colorectal cancer in adults at average risk: a summary of the evidence for the U.S. Preventive Services Task Force. Annals of Internal Medicine. 2002;137(2):132-41. [pmid: 12118972].
52 CDC. Annual Smoking-Attributable Mortality, Years of Potential Life Lost, and Economic Costs --- United States, 1995--1999. 51, 300. 2002. Atlanta, GA. MMWR.
53 Schoenborn CA, Adams PF, Barnes PM, Vickerie JL, Schiller JS. Health Behaviors of Adults: United States, 1999-2001. 10 ed. National Center for Health Statistics. Vital Health Stat., 2004. Companion table 4.1 (Internet Release Only). Accessed at http://www.cdc.gov/nchs/data/series/sr_10/sr10_219companion.pdf on 15 November 2004/.
54 Table: Age Groups and Sex: 2000 Summary File 1 100-Percent data. US Census Data. 2001. Accessed at www.factfinder.census.gov on 15 November 2004.
55 Gorelick P B. Cerebrovascular disease in African Americans. Stroke. 1998;29(12):2656-2664. [pmid: 9836782].
56 Spencer C A, Jamrozik K, Norman P E, Lawrence-Brown M M. The potential for a selective screening strategy for abdominal aortic aneurysm. Journal of Medical Screening. 2000;7(4):209-211. [pmid: 11202589].
57 Lederle F A. Ultrasonographic screening for abdominal aortic aneurysms. Annals of Internal Medicine. 2003;139(6):516-522. [pmid: 13679330].
58 Crow P, Shaw E, Earnshaw J J, Poskitt K R, Whyman M R, Heather B P. A single normal ultrasonographic scan at age 65 years rules out significant aneurysm disease for life in men. Br J Surg. 2001;88(7):941-944. [pmid: 11442524].
59 Emerton M E, Shaw E, Poskitt K, Heather B P. Screening for abdominal aortic aneurysm: a single scan is enough. British Journal of Surgery. 1994;81(8):1112-1113. [pmid: 7953333].
60 Lederle F A, Johnson G R, Wilson S E, Littooy F N, Krupski W C, Bandyk D, et al. Yield of repeated screening for abdominal aortic aneurysm after a 4-year interval. Aneurysm Detection and Management Veterans Affairs Cooperative Study Investigators. Archives of Internal Medicine. 2000;160(8):1117-1121. [pmid: 10789604].
61 Lindholt J S, Vammen S, Fasting H, Henneberg E W. Psychological consequences of screening for abdominal aortic aneurysm and conservative treatment of small abdominal aortic aneurysms. European Journal of Vascular & Endovascular Surgery. 2000;20(1):79-83. [pmid: 10906303].
62 Lucarotti M E, Heather B P, Shaw E, Poskitt K R. Psychological morbidity associated with abdominal aortic aneurysm screening. European Journal of Vascular & Endovascular Surgery. 1997;14(6):499-501. [pmid: 9467527].
63 Kent K C, Zwolak R M, Jaff M R, Hollenbeck S T, Thompson R W, Schermerhorn M L, et al. Screening for abdominal aortic aneurysm: a consensus statement. J Vasc Surg. 2004;39(1):267-269. [pmid: 14718853].
64 Hollier L H, Taylor L M, Ochsner J. Recommended indications for operative treatment of abdominal aortic aneurysms. Report of a subcommittee of the Joint Council of the Society for Vascular Surgery and the North American Chapter of the International Society for Cardiovascular Surgery. Journal of Vascular Surgery. 1992;15(6):1046-1056. [pmid: 1597887].
65 Brewster D C, Cronenwett J L, Hallett J W Jr, Johnston K W, Krupski W C, Matsumura J S, et al. Guidelines for the treatment of abdominal aortic aneurysms. Report of a subcommittee of the Joint Council of the American Association for Vascular Surgery and Society for Vascular Surgery. Journal of Vascular Surgery. 2003;37(5):1106-1117. [pmid: 12756363].
66 Ballard DJ, Etchason JA, Hillborne L.H., Campion M.E., Kamberg C.J., Solomon D.H. et al. Abdominal aortic aneurysm surgery: a literature review and ratings of appropriateness and necessity. 1992. Santa Monica, CA, The RAND Corporation. 1992.
67 United Kingdom Small Aneurysm Trial Participants. Long-term outcomes of immediate repair compared with surveillance of small abdominal aortic aneurysms. New England Journal of Medicine. 2002;346(19):1445-1452. [pmid: 12000814].
68 Blankensteijn J D, Lindenburg F P, van der G Y, Eikelboom B C. Influence of study design on reported mortality and morbidity rates after abdominal aortic aneurysm repair. Br J Surg. 1998;85(12):1624-1630. [pmid: 9876063].
69 Huber T S, Wang J G, Derrow A E, Dame D A, Ozaki C K, Zelenock G B, et al. Experience in the United States with intact abdominal aortic aneurysm repair. Journal of Vascular Surgery. 2001;33(2):304-310. [pmid: 11174782].
70 Dimick J B, Cowan J A Jr, Stanley J C, Henke P K, Pronovost P J, Upchurch G R Jr. Surgeon specialty and provider volumes are related to outcome of intact abdominal aortic aneurysm repair in the United States. Journal of Vascular Surgery. 2003;38(4):739-744. [pmid: 14560223].
71 Lederle F A, Johnson G R, Wilson S E, Acher C W, Ballard D J, Littooy F N, et al. Quality of life, impotence, and activity level in a randomized trial of immediate repair versus surveillance of small abdominal aortic aneurysm. Journal of Vascular Surgery. 2003;38(4):745-752. [pmid: 14560224].
72 United Kingdom Small Aneurysm Trial Participants. Health service costs and quality of life for early elective surgery or ultrasonographic surveillance for small abdominal aortic aneurysms. Lancet. 1998;352(9141):1656-1660. [pmid: 9853437].
73 Parodi J C, Palmaz J C, Barone H D. Transfemoral intraluminal graft implantation for abdominal aortic aneurysms. Annals of Vascular Surgery. 1991;5(6):491-499. [pmid: 1837729].
74 Rutherford R B, Krupski W C. Current status of open versus endovascular stent-graft repair of abdominal aortic aneurysm. Journal of Vascular Surgery. 2004;39(5):1129-1139. [pmid: 15111875].
75 Prinssen M, Buskens E, Blankensteijn J D. The Dutch Randomised Endovascular Aneurysm Management (DREAM) trial. Background, design and methods. Journal of Cardiovascular Surgery. 2002;43(3):379-384. [pmid: 12055570].
76 Brown L C, Epstein D, Manca A, Beard J D, Powell J T, Greenhalgh R M. The UK Endovascular Aneurysm Repair (EVAR) trials: design, methodology and progress. European Journal of Vascular & Endovascular Surgery. 2004;27(4):372-381. [pmid: 15015186].
77 Buth J M, Laheij R J F. on behalf of the EUROSTAR Collaborators. Early complications and endoleaks after endovascular abdominal aortic aneurysm repair: Report of a multicenter study. J Vasc Surg. 2000;31(1, Part 1):134-146. [pmid: 10642716].
78 Thomas S M, Gaines P A, Beard J D. Vascular Surgical Society of Great Britain and Ireland, British Society of Interventional Radiology. Short-term (30-day) outcome of endovascular treatment of abdominal aortic aneurism: results from the prospective Registry of Endovascular Treatment of Abdominal Aortic Aneurism (RETA). European Journal of Vascular & Endovascular Surgery. 2001;21(1):57-64. [pmid: 11235667].
79 Lifeline Registry of Endovascular Aneurysm Repair Steering Committee. Lifeline Registry: collaborative evaluation of endovascular aneurysm repair. Journal of Vascular Surgery. 2001;34(6):1139-1146. [pmid: 11780606].
80 The EVAR trial participants. Comparison of endovascular aneurysm repair with open repair in patients with abdominal aortic aneurysm (EVAR trial 1), 30-day operative mortality results: randomised controlled trial. Lancet. 2004;364:843-848. [pmid: 15351191].
81 Huber T S M P, Seeger J M M. Dartmouth Atlas of Vascular Health Care review: Impact of hospital volume, surgeon volume, and training on outcome. J Vasc Surg. 2001;34(4):751-756. [pmid: 11668335].
82 Akkersdijk G J, Prinssen M, Blankensteijn J D. The impact of endovascular treatment on in-hospital mortality following non-ruptured AAA repair over a decade: a population based study of 16,446 patients. Eur J Vasc Endovasc Surg. 2004;28:41-46. [pmid: 15177230].
83 Adriaensen M E, Bosch J L, Halpern E F, Myriam Hunink M G, Gazelle G S. Elective endovascular versus open surgical repair of abdominal aortic aneurysms: systematic review of short-term results. Radiology. 2002;224(3):739-747. [pmid: 12202708].
84 Buth J, Laheij R J. Early complications and endoleaks after endovascular abdominal aortic aneurysm repair: report of a multicenter study. Journal of Vascular Surgery. 2000;31(1 Pt 1):134-46. [pmid: 10642716].
85 Harris P L, Vallabhaneni S R, Desgranges P, Becquemin J P, van Marrewijk C, Laheij R J. Incidence and risk factors of late rupture, conversion, and death after endovascular repair of infrarenal aortic aneurysms: the EUROSTAR experience. European Collaborators on Stent/graft techniques for aortic aneurysm repair. J Vasc Surg. 2000;32(4):739-749. [pmid: 11013038].
86 Lifeline Registry of Endovascular Aneurysm Repair Steering Committee. Lifeline Registry of Endovascular Aneurysm Repair: Registry data report. Journal of Vascular Surgery. 2002;35(3):616-620. [pmid: 11877719].