# Conclusion

Table 9 summarizes the overall strength and quality of evidence according to the USPSTF criteria (Appendix 4).^40^ We reviewed four good or fair quality randomized, controlled trials of population-based AAA screening in 126 000 men that provide Level I evidence that screening significantly reduces AAA-related mortality in men age 65 to 80 years (summary OR from meta-analysis 0.57; 95% CI, 0.45–0.74). Data on all-cause mortality were available for two of the four trials reviewed. In meta-analysis of the three available trials, no significant reduction in all-cause mortality was evident with screening (summary OR 0.98; 95% CI, 0.95–1.02). We modeled expected outcomes of screening for AAA based on a hypothetical cohort of 65–74 year-old men. The NNS to prevent one AAA-related death was 648 (estimated upper and lower limits 506–1072). One study from the UK included 9342 women and showed no differences in AAA-related outcomes.

Table 9. Summary of Evidence Quality for Screening for Abdominal Aortic Aneurysm

| Key Question | Study Hierarchy | Overall USPSTF Quality
1a. | AAA screening | I | Fair-to-good
1b. | Repeat screening | II-2
2. | Screening harms | II-2
3. | Harms of treatment ≥ 5.5 cm | II-2 | Good
4. | Treatment 4.0–5.4 cm AAA | I
5. | Harms treatment 3.0–5.4 cm AAA | II-2

A history of smoking is the most significant risk factor distinguishing populations at higher risk for AAA (OR 5.07 for AAA ≥ 4.0 cm; 95% CI, 4.13–6.21). While it is likely that the benefit of population screening is related to prevalence as predicted by AAA risk factors such as smoking, we unfortunately have no direct trial evidence in this regard. We constructed a model to estimate benefits by smoking status for a hypothetical cohort of 65–74 year-old men using US data on lifetime smoking prevalence. Assuming that never-smokers and ever-smokers with AAAs experienced the same risk of AAA-related death and the same benefit of screening, we estimated that 89% of AAA-related deaths occur in ever-smokers. We estimated the NNS to prevent one AAA-related death to be 500 in ever-smokers compared to 1783 in never-smokers.

No significant physical harms were associated with screening. Those found to have AAAs ≥ 3.0 cm during screening initially had more anxiety, lower self-rated health status, and lower self-rated quality of life than those with negative scans. However, these changes tended to be within norms of ratings found in the general population and were no longer present after six weeks.

For individuals who are found to have an AAA ≥ 5.5 cm, immediate surgical repair is warranted provided the patient is fit for surgery. Periodic surveillance appears reasonable for those with 3.0–3.9 cm AAAs, which have a very low risk of rupture. For 4.0–5.4 cm AAAs, immediate surgical repair, compared to surveillance with delayed repair, does not appear to improve either AAA-related mortality or all-cause mortality. The yearly rupture rate of such AAAs with surveillance is 1% or less. In both trials, patients in the immediate repair group had higher scores for self-reported general health status compared to those undergoing surveillance. In the ADAM trial, those undergoing immediate repair reported significantly more impotence after one year, and a greater rate of decline in maximum activity level than did those in the surveillance group.

Open repair of AAAs may result in significant risk of operative mortality as well as such adverse outcomes as cardiac, pulmonary and other complications. Open repair is associated with better outcomes when performed by specialty surgeons in high-volume hospitals.

EVAR appears to reduce short-term morbidity and mortality compared to open repair and may be the preferred procedure for intact AAA repair in some patients. Long-term complications, including AAA rupture and the need of subsequent open repair, may result in significant long-term morbidity and mortality. Periodic surveillance with computed tomography to monitor for complications may also be required for the remainder of the patients' lifetime. Several randomized clinical trials are ongoing, comparing long-term outcomes of EVAR to open repair for AAAs ≥ 5.5 cm. These trials may provide a better understanding of the balance of benefits and harms for patients undergoing EVAR.

We are not aware of ongoing clinical trials of EVAR for 4.0–5.4 cm AAAs, although more than 20% of EVAR procedures are currently performed in such patients.^86^ In the ADAM trial, no significant difference was found in AAA-related or all-cause mortality at eight years for patients undergoing immediate repair compared to periodic surveillance. It is not clear what benefit EVAR may offer for individuals with small AAAs, since the 30-day operative mortality for immediate surgical repair in the ADAM trial of 1.8% was similar to the 30-day operative mortality rate of 1.7% for EVAR recently reported from the EVAR 1 trial.

The screening trials we evaluated compared outcomes of screening in populations. Because the screened group included both patients who were scanned and those who were not, these trials do not allow us to estimate an individual patient's benefit from attending screening and having an ultrasound scan for AAA. A variety of factors, such as fitness to undergo interventions smoking history, age, family history, and comorbidities are important in determining the individual benefit from screening. Primary care providers may need to consider such factors in discussions to inform a patient's screening decision.