# Results

## Key Question 1a. Does AAA screening in an asymptomatic average-risk or high-risk population reduce AAA-related adverse health outcomes?

Our search strategy for question 1a identified four randomized, controlled trials that assessed the efficacy of AAA screening in population-based settings: the Multicentre Aneurysm Screening Study (MASS) from the United Kingdom;^11^ the Chichester, United Kingdom screening trial;^14,^ ^44,^ ^45^ the Viborg County, Denmark screening trial;^37^ and the Western Australia screening trial.^12,^ ^36,^ ^46^

### Trial Characteristics

Table 1 presents the characteristics of the four screening trials. All trials identified potential participants aged 65 years or older at average risk for AAA through population registries or regional health directories. Different stopping ages were used for each trial, ranging from 73–83 years. All trials identified potential participants age 65 years or older at average risk for AAA through population registries or regional health directories. The 4 trials included more than 125 000 total participants. Different stopping ages were used for each trial and ranged from 73 years to 83 years. No data were provided on race or ethnicity. Only the Chichester trial included women.

Table 1. Summary of AAA Screening Trials

Trial | MASS | Western Australia | Viborg | Chichester, Men | Chichester, Women
Reference | Ashton, 2002^11^ | Norman, 2004^36^ | Lindholt, 2002^37^ | Scott, 1995^44^ | Scott, 1995^44^
Location | UK | Australia | Denmark | UK | UK
Recruitment | Population screening | Population screening | Population screening | Population screening | Population screening
Age | 65–74 years | 65–83 years | 65–73 years | 65–80 years | 65–80 years
Gender | Male | Male | Male | Male | Female
Ethnicity | Unknown | > 90% Caucasian | 100% Caucasian | Unknown | Unknown
Total Randomized | 67,800 | 38,704 | 12,658 | 6,433 | 9,342
Duration of Follow-up, Year | 4.1 | 3.6 | 5.1 | 2.5 | 2.5
Invited for Screening | 33,839 | 19,352 | 6339 | 3,205 | 4,682
Screened, % | 80% | 63% | 69% | 73% | 65%
Uninvited Controls | 33,961 | 19,352 | 6,319 | 3,228 | 4,660
Ascertainment of Outcomes
Death Registry | Yes | Yes | No | Yes | Yes
Hospital Records | Yes | Yes | Yes | Yes | Yes
Outcomes ascertained, % | 99% | 99%§ | 100% | Not reported | Not reported
Quality | Good | Fair | Fair* | Fair | Fair

§ Provided by author.

* Only hospital records available to ascertain outcomes

In MASS and in the Chichester and Western Australia trials, participants were excluded before randomization if they resided in nursing homes. In MASS and in the Chichester trial, participants were also excluded before, and without knowledge of, randomization if their primary physician deemed them unfit for elective AAA repair. Participants were then randomly assigned to an intervention group that received an invitation to attend screening or to a control group that received “usual care.” All control group participants were followed passively and without contact. Across the 4 trials, 63% to 80% of invited participants attended ultrasound scanning. On an intention-to-treat basis, those who were invited to screening but did not attend were also included in the analysis.

In the MASS, Chichester, and Viborg trials, patients with AAAs exceeding a threshold size of 5.0 to 6.0 cm on initial measurement were referred to a vascular surgeon. Patients with smaller AAAs were periodically re-scanned and referred to a vascular surgeon for AAAs that had expanded to or above the threshold size on follow-up scanning. In the MASS and Chichester trials, patients were also referred if the AAA expanded rapidly (≥ 1.0 cm in 1 year) or became symptomatic. Participants with normal size aortas (<3.0 cm) on initial scan received no further follow-up. In the MASS trial, 31 of 354 (18%) invited group patients undergoing elective AAA repairs did not meet trial criteria for referral based on size. Crossover data were not available for other trials. In the Western Australia trial, each patient attending screening was given a letter with his results, as well as a letter for his physician with results and management guidelines suggesting yearly rescanning for 3.0 to 3.9 cm AAAs, twice yearly scanning or vascular surgery referral for 4.0 to 4.9cm AAAs, and vascular surgery referral for AAAs ≥ 5.0 cm. For patients with AAAs ≥ 4.5 cm, a letter was also mailed to the patient's personal physician. Subsequent examinations and vascular surgery referral were left to the discretion of the patient and his physician. The investigators had no further contact with participants in either the group invited to screening, whether scanned or not, or the control group participants.

Each trial, except the Viborg study, used a combination of hospital records and death certificate registries to ascertain outcomes for both invited and control participants. The Viborg study ascertained outcomes using only hospital records from the regional hospital in Viborg County, Denmark. Use of death certificates to classify cause of death is prone to bias.^47^ In these studies, this bias may be conservative. Private physicians were informed if patients invited to attend screening were diagnosed with AAAs, and thus may have been more likely to attribute more sudden death in these patients to AAAs than were physicians of uninvited controls. This ascertainment bias may make an advantage due to screening more difficult to detect.^5^

### Assessment of Study Quality

Table 2 presents quality parameters for each trial based on defined USPSTF criteria.^40^ In all trials, the individual participant was the unit of randomization and randomization methods were adequate. Due to the nature of the trials, blinding of participants and care providers to the screening results was not possible. MASS was assigned a “Good” quality rating based on USPSTF criteria. An independent working party that apparently was not aware of participant assignment, ascertained outcomes based on death registries. The Viborg study, the Chichester study, and Western Australia study were assigned “Fair” quality ratings. These trials did not report important information, such as baseline characteristics and whether outcomes assessors were blinded.

Table 2. Quality of Randomized Trials of Screening for AAA

Trial | MASS | Western Australia | Viborg | Chichester
Reference | Ashton, 2002^11^ | Norman, 2004^36^ | Lindholt, 2002^37^ | Scott, 1995^44^
Randomization | Yes, by individual | Yes, by individual | Yes, by individual | Yes, by individual
Allocation Concealed | Yes | Yes | Yes | Yes
Groups Similar at Baseline | Yes | Yes | Not stated | Not stated
Eligibility Criteria Specified | Yes | Yes | Yes | Yes
Outcomes Assessors Blinded | Yes | Not stated | Not stated | Not stated
Care Provider Blinded | Not possible due to type of study
Patient Unaware of Treatment | Not possible due to type of study
Maintenance of Comparable Groups | Follow-up data not available for control group
Reporting of Loss to Follow-up | Yes | Yes | Yes | Yes
Differential Loss to Follow-up | Not possible due to type of study
Intention-to-Treat Analysis | Yes | Yes | Yes | Yes
Statistical Analysis Appropriate | Yes | Yes | Yes | Yes
Score | Good | Fair | Fair | Fair
Comments | | Fair: methods for outcomes assessment not reported | Fair: baseline characteristics and methods for outcomes assessment not reported; outcomes from hospital records only | Fair: baseline characteristics and methods for outcomes assessment not reported

MASS, Multicentre Aneurysm Screening Study.

In MASS, the Western Australia study, and the Viborg study, outcomes were ascertained for 99% to 100% of all participants. These data were not reported for the Chichester study. In the Viborg study, only hospital records were available to assess these outcomes. In all studies, analyses were based on intent-to-treat. Outcomes for both attendees and non-attendees were included in the analyses for the invited for screening group.

While the Chichester trial also reported outcomes for 10 years of follow-up,^14,^ ^45^ we did not include these data because the number of patients differed from the number of patients reportedly randomized in the paper detailing the 5-year results.^44^

### Effect of Population Screening on AAA-Related Mortality

Table 3 presents the results of the four trials of AAA screening. All trials had ORs favoring an association between an invitation to attend screening and a reduction in AAA-related deaths. The association was significant in MASS (OR, 0.58; 95% CI, 0.42 to 0.78) and in the Viborg County study (OR, 0.31; 95% CI, 0.13 to 0.79). We examined the impact of an invitation to attend screening on AAA-related mortality for men by pooling trial results using meta-analysis (Figure 2). The pooled OR showed a reduction in AAA-related mortality favoring screening (OR, 0.57; 95% CI, 0.45 to 0.74). The Multicentre Aneurysm Screening Study, the largest of the trials and the trial with the narrowest CI, contributed the most weight to the pooled OR. In sensitivity analyses, removing any of the other 3 studies, separately or in combination, had very little impact on the pooled OR and CI. When the MASS trial was removed from the meta-analysis, however, the pooled meta-analysis based on the other 3 studies still showed a significant reduction in AAA-related mortality (OR, 0.56;95% CI, 0.36 to 0.88).

Table 3. Results of AAA Screening Trials

Study | MASS | Western Australia | Viborg | Chichester, Men | Chichester, Women | Pooled Estimates for Men over 65
Reference | Ashton, 2002^11^ | Norman, 2004^36^ | Lindholt, 2002^37^ | Scott, 1995^44^ | Scott, 1995^44^
Invited for Screening | 33,839 | 19,352 | 6339 | 3,205 | 4,682
Scanned | 27,147 | 12,203 | 4843 | 2,342 | 3,052
Accepted Screening, % | 80% | 63% | 69% | 73% | 65% | 72%
AAA in Scanned, n (%) | 1330 (4.9%) | 875 (7.2%) | 191 (4.0%) | 178 (7.6%) | 40 (1.3%) | 5.5%
Uninvited Controls | 33,961 | 19,352 | 6,319 | 3,228 | 4,660
Duration of Follow-up, Yr | 5 | 2.5 | 5 | 5 | 5
[underlined: AAA-Specific Mortality]
Invited | 65 (0.19%) | 18 (0.09%) | 6 (0.09%) | 10 (0.31%) | 2 (0.04%)
Controls | 113 (0.33%) | 25 (0.13%) | 19 (0.30%) | 17 (0.36%) | 2 (0.04%) | 0.72 per 1000 person-years
OR* (95% CI) | 0.58 (0.42, 0.78) | 0.72 (0.39,1.32) | 0.31 (0.13, 0.79) | 0.59 (0.27,1.29) | 1.00 (0.14, 7.07) | 0.57 (0.45, 0.74)
[underlined: All-cause Mortality]
Invited | 3750 (11.1%) | 1976 (10.2%) | - | 532 (16.6%) | 503 (10.7%)
Controls | 3855 (11.4%) | 2020 (10.4%) | - | 508 (15.7%) | 476 (10.2%)
OR* (95% CI) | 0.97 (0.93, 1.02) | 0.98 (0.91, 1.04) | - | 1.07 (0.93, 1.22) | 1.05 (0.92, 1.19) | 0.98 (0.95, 1.02)
[underlined: Elective Repair]
Invited | 332 (0.98%) | 107 (0.55%) | 50 (0.79%) | 28 (0.87%) | 4 (0.08%) | 0.96% (0.88%,1.06%)
Controls | 92 (0.27%) | 54 (0.28%) | 14 (0.22%) | 5 (0.15%) | 2 (0.04%) | 0.28% (0.24%, 0.34%)
[underlined: Emergency Repair]
Invited | 27 (0.08%) | 9 (0.05%) | 6 (0.09%) | 3 (0.09%) | 1 (0.02%) | 0.11% (0.08%, 0.14%)
Controls | 54 (0.16%) | 8 (0.04%) | 30 (0.47%) | 8 (0.24%) | 1 (0.01%) | 0.23% (0.19%, 0.28%)
[underlined: AAA Rupture]
Invited | 67 (0.20%) | 33 (0.17%) | 4 (0.10%) | 8 (0.25%) | 3 (0.06%) | 0.18% (0.15%, 0.23%)
Controls | 134 (0.40%) | 38 (0.20%) | 20 (0.3%) | 20 (0.62%) | 2 (0.04%) | 0.40% (0.35%, 0.46%)
[underlined: Operative Mortality]
Elective Repair % | 6% | 4.3% | 6% | 0% | 0% | 6%
Urgent/Emergent Repair % | 37% | 50% | 39% | 25% | 33% | 37%

CI, confidence interval, MASS, Multicentre Aneurysm Screening Study; OR, odds ratio.

* Odds ratios were obtained by pooling trials for men using random effects meta-analyses.

Figure 2. Meta-Analysis of AAA-Related Deaths in Population Screening Trials

### Effect of Population Screening on All-Cause Mortality

All-cause mortality results for men were available for MASS and for the Western Australia and Chichester trials (Figure 3). When the results of the 3 trials were pooled, an invitation to attend screening was associated with a nonsignificant reduction in all-cause mortality (OR, 0.98; 95% CI, 0.95 to 1.02).

Figure 3. Meta-Analysis of All-Cause Mortality in Population Screening Trials

### Population Screening for AAA in Women

The Chichester trial included 9342 women aged 65 to 80 years who were randomized to either an invitation-to-screening or control group (Table 3).^44^ No other trials included women. Sixty-five percent of women attended screening compared to 73% of men (p<0.0001). The prevalence of AAA in the women who were scanned was 1.3% compared to 7.6% in men. At five years of follow-up, there were no differences between women invited for screening and the control group in either AAA-related mortality (OR 1.0; 95% CI, 0.14–7.07) or all-cause mortality (OR 1.05; 95% CI, 0.92–1.19). At ten years, the incidence of AAA rupture was the same for women in both the screening and control groups.^14^ In men, the majority of deaths from AAA rupture occurred in those younger than 80 years of age. In contrast, for women, seventy percent of deaths from AAA rupture occurred after the age of 80.

### Modeling of Outcomes for AAA Screening

Table 4 presents outcomes for population invited to attend AAA screening versus no invitation for a hypothetical cohort of 100 000 men age 65 to 74 years followed over five years (the mean follow-up interval for the four trials combined). Pooled estimates of odd ratios and event rates were taken from Table 3. Confidence intervals were used to estimate a lower and upper bound of benefit for each event. Life expectancy was calculated using life-table methods and assumes that AAA screening reduces all-cause mortality at a constant rate throughout the men's lives.

Table 4. 5-Year Outcomes of AAA Screening in a Cohort of 100,000 Men Aged 65–74 Years

Assumptions* | Baseline | Lower 95% CI | Upper 95% CI
AAA Prevalence | 5.5%
Screening Attendance | 72.0%
AAA-Related Deaths, 1000 person-years | 0.72
OR AAA-related death with screening | 0.57 | 0.45 | 0.74
All-Cause Deaths, 1000 person-years | 28.70
OR deaths from all causes | 0.98 | 0.95 | 1.02
AAA-ruptures
No Screening Program | 0.40% | 0.35% | 0.46%
With Screening Program | 0.18% | 0.15% | 0.23%
Elective Surgery
No Screening Program | 0.28% | 0.24% | 0.34%
With Screening Program | 0.96% | 0.88% | 1.06%
Emergency Surgery
No Screening Program | 0.23% | 0.19% | 0.28%
With Screening Program | 0.11% | 0.08% | 0.14%
Operative Mortality
Elective AAA repair | 6% | 6% | 6%
Emergency AAA repair | 37% | 37% | 37%
Results | Baseline | Lower bound | Upper bound
Total AAAs in Cohort | 5,500 | 5,500 | 5,500
[underlined: AAA-Related Deaths, n]
No Screening Program | 359 | 359 | 359
[underlined: With Screening Program] | [underlined: 205] | [underlined: 162] | [underlined: 266]
AAA Deaths Prevented | 154 | 197 | 93
NNS to Prevent 1 Death from AAA | 648 | 506 | 1,072
[underlined: Deaths from All Causes, n]
No Screening Program | 13,368 | 13,368 | 13,368
[underlined: With Screening Program] | [underlined: 13,119] | [underlined: 12,744] | [underlined: 13,616]
All-Cause Deaths Prevented (Caused) | 249 | 624 | (248)
[underlined: Elective Surgical Procedures, n]
Invited for Screening | 960 | 880 | 1060
Not Screened | 280 | 240 | 340
[underlined: Emergency Surgical Procedures, n]
Not Screened | 230 | 190 | 280
Invited for Screening | 110 | 80 | 140
[underlined: AAA Ruptures, n]
No Screening Program | 400 | 350 | 460
[underlined: With Screening Program] | [underlined: 180] | [underlined: 150] | [underlined: 230]
AAA Ruptures Prevented | 220 | 200 | 230
NNS to Prevent 1 AAA Rupture | 455 | 435 | 500
[underlined: Deaths, Elective Surgery, n]
No Screening Program | 17 | 14 | 20
With Screening Program | 58 | 53 | 64
[underlined: Deaths, Emergency Surgery, n]
No Screening Program | 85 | 70 | 104
With Screening Program | 41 | 30 | 52
[underlined: Total Surgical Deaths, n]
No Screening Program | 102 | 85 | 124
With Screening Program | 98 | 82 | 115

CI, confidence interval, NNS, number needed to screen.

* OR = Odds ratio with screening program compared to no screening program. Estimates of event rates and relative risks incorporate variability across screening trials in prevalence, acceptance of screening, accuracy of screening, and adherence to clinical management protocols for surgery and surveillance.

The prevalence of AAAs averaged across all four trials was 5.5%. Based on the average estimate across trials from Table 3, 72 % of men invited for screening would attend and undergo ultrasound scanning. Sensitivity analyses on screening attendance rates could not be performed, however, since men who attend screening may be significantly different those who do not in terms of age, comorbidities, and socioeconomic status.^48,^ ^49^ We used the summary odds ratios from the combined trials (Figures 2 and 3) to estimate the treatment effect arising from an invitation to screening. These estimates incorporate variability, both within and between trials, in a number of factors. Also note that these estimates do not reflect the benefit of ultrasound scanning of an AAA in a particular individual.

Among the 100 000 men in the hypothetical cohort, an expected 5500 men would have an AAA. If the cohort were invited for screening, 3960 of 5500 AAAs would be detected based on a 72% acceptance rate. Based on the combined AAA-mortality rate from Table 3 (0.72 deaths per 1000 person-years), 359 AAA-related deaths would be expected with no screening over five years. If the cohort were invited to screening, the number of AAA-related deaths would be reduced to 205 over 5 years, and one AAA-related death would be prevented among every 648 men invited for screening. Based on the 95% confidence interval for the pooled odds ratio, 506 to 1072 men would need to be invited to screening to prevent one AAA-related death. For comparison, the number needed-to-invite to mammography to prevent one breast cancer death ranges from 345 to 3468.^50^ The needed-to-invite to undergo screening to prevent one colorectal cancer death ranges from 345 to 1250.^51^

Without screening, 13 368 men would be expected to die from all causes over five years. At baseline, the summary odds ratio from the meta-analysis for all-cause mortality is 0.98 (95% CI, 0.95 to 1.02), and the screening program would result 249 excess all-cause deaths prevented. At the upper bound of the confidence interval, screening would result in 248 excess all-cause deaths and reduce average life expectancy by seven months per individual invited to screening. At the lower bound of the confidence interval, 624 additional lives would be saved as a result of screening with a gain in average life expectancy of seven months.

As expected, more AAA ruptures will occur if the cohort is not screened. The NNS to prevent one AAA rupture ranges from 435 to 500 men. More elective repairs than emergency repairs will be performed if the cohort is screened, and vice versa with no screening. Thus, screening results in more deaths from elective repair and fewer from emergency repair, and there are fewer deaths from elective repair and more from emergency repair without screening.

### Screening for AAA in High-Risk Subgroups

Risk factors for AAA ≥ 4.0 cm, based on multivariate odds ratio from a screening study of 126 696 US veterans,^13^ included a history of regular smoking (OR 5.07; 95% CI, 4.13–6.21); family history (OR 1.94; 95% CI, 1.63–2.32); age (OR 1.71 per 7-year age interval; 95% CI, 1.61–1.82); coronary artery disease (OR 1.52; 95% CI, 1.37–1.68); hypercholesterolemia (OR 1.44; 95% CI, 1.27–1.63); and cerebrovascular disease (OR 1.28; 95% CI, 1.11–1.47). Significant negative risk factors were female gender (OR 0.17; 95% CI, 0.07–0.48); diabetes mellitus (OR 0.52; 95% CI, 0.45–0.61); and black race (OR 0.53; 95% CI, 0.40–0.69).

A history of smoking is the most significant risk factor distinguishing populations at higher risk for AAA. Figure 4 shows the prevalence of AAAs by age and smoking history from the same screening study.^13^ Ever-smokers are defined based on the CDC's definition as those who have smoked more than 100 cigarettes during their lifetime.^52^ Overall, the prevalence of aneurysms ≥ 3.0 cm was 5.1% in ever-smokers versus 1.5% in never smokers (unadjusted OR 3.6; 95% CI 3.3, 4.0). In never-smokers, AAA prevalence was more strongly associated with age compared to ever-smokers; the mean age of those with AAA who never smoked was 73 years, compared to 69 years for ever-smokers. In a systematic review and meta-analysis, Lederle et al. also found a strong association between smoking history and the risk of AAA-related mortality.^25^

Figure 4. Prevalence of AAAs > 3.0 cm by Age and Smoking History

In Table 5, we model the impact of an invitation to attend screening based on smoking status in a hypothetical cohort of 100 000 US males aged 65 years. About 31% of men in the US aged 65–74 years have never smoked.^53^ We use the average 5.5% prevalence of AAA derived from the four population-based screening trials (Table 3). Based on aneurysm prevalence data for 65–74 year old veterans from the veteran's screening study, the prevalence of AAA ≥ 3.0 cm is 6.4% for ever-smokers compared to 1.8% for never-smokers.^13^ To model screening benefits, we use the combined odds ratios for reduction of AAA-related mortality from the four population screening trials (Figure 2). We assume that ever-smokers and never-smokers equally benefit from reduction in AAA-specific mortality. In this age cohort, inviting only those with a history of smoking to screening will detect approximately 89% of prevalent AAAs. Without screening, AAA-related death over five years is expected in 320 of 69 000 (0.46%) of ever-smokers and 40 of 31 000 (0.13%) of never-smokers. Assuming that an invitation to screening reduces ever-smokers and never-smokers AAA-related mortality equally, the NNS to prevent one AAA-related death with screening is 645 men in the entire cohort, 500 in men who have ever smoked and 1783 in those with no smoking history. Based on 8 300 000 men 65–74 years in the US from the year 2000 census,^54^ an invitation to screening would prevent an estimated 12 831 AAA-related deaths over five years, with a reduction of 11 392 AAA-related deaths (89%) attributable to screening men with a history of smoking.

Table 5. 5-Year Outcomes of AAA Screening by Smoking History in a Cohort of 100,000 Men Age 65–74 Years

Assumptions | Ever Smokers | Never Smokers | Total Cohort
Lifetime Smoking History, % | | | 69%
AAA Prevalence in Men Age 65–74 years,%
Ever Smokers | | | 6.4%
Never Smokers | | | 1.8%
AAA-Related Deaths Per 1000 Person-Years | | | 0.72
OR AAA-Related Death with Screening | | | 0.57
U.S. Male Population 65–74 (millions)* | | | 8.3
[underlined: Results]
Total AAAs in Cohort | 4,416 | 558 | 4,974
AAA-Related Deaths, n
Not Screened | 320 | 40 | 360
[underlined: Invited for Screening] | [underlined: 182] | [underlined: 23] | [underlined: 205]
AAA Deaths Prevented | 138 | 17 | 155
NNS to Prevent 1 Death from AAA | 500 | 1,783 | 645
Estimated 5-Year AAA-Related Deaths in the U.S. Male Population Aged 65–74 Years, n
Not Screened | 26,521 | 3,351 | 29,872
[underlined: Invited for Screening] | [underlined: 15,129] | [underlined: 1,912] | [underlined: 17,041]
AAA deaths prevented by screening | 11,392 | 1,439 | 12,831
% AAA-attributable deaths | 89% | 11%

NNS, number needed to screen; OR, odds ratio.

* Source: Age Groups and Sex 2000. Summary File 1 100-Percent Data. U.S. Census Data. 2001. Accessed at www.factfinder.census.gov on 15 November 11/15/2004.

Black race is a negative risk factor for AAAs. In the Veterans Affairs (VA) Aneurysm Detection and Management (ADAM) screening study, with adjustment for other factors, such as age and smoking, the odds ratio for AAAs ≥ 4.0 cm was 0.49 (95% CI 0.39–0.69) for blacks compared to whites.^15^ Age-adjusted AAA death rates for black males are also less than one-half of those for white males, although death rates for dissecting aneurysms and thoracic aneurysms are similar.^3^ The reason that black race appears protective for AAA is not clear. Blacks have a higher burden than whites of atherosclerotic risk factors, such as hypertension and diabetes.^55^ The lower incidence of AAA in blacks may then be consistent with the hypothesis that atherosclerosis is not the primary pathogenic process in AAA formation.^22^

The potential for selective screening has been examined in the Viborg screening trial^10^ and the Western Australia screening trial.^56^ In the Viborg trial, 72 of 141 AAA (51.1%) were found in men who had one or more risk factors including a history of hypertension, acute myocardial infarction, angina pectoris, chronic obstructive pulmonary disease, cerebrovascular disease, or lower limb atherosclerosis. The Western Australia trial investigators gathered data on risk factors in the first 8995 men aged 65 to 83 years, who accepted an invitation for screening. Using this data, they developed a multivariate risk score with ten risk factors; this score was then applied in the next 2755 men who were scanned. Screening 50% of men in the second cohort based on the risk score would have missed 25% of AAAs present in the sample population. Using a history of smoking alone would identify most AAAs but would reduce those screened by only 34%, which may not greatly reduce the screening workload.^57^

### Factors Influencing Attendance at Ultrasonography Screening for AAA

Investigators in the Viborg and MASS screening trials examined factors associated with attendance in those invited for ultrasound screening. In the Viborg study, age had a significant impact on screening attendance, which fell steadily from 81.1% in 65 year-old men to 65.1% in 73 year-old men.^49^ The attendance rate was 80.5% in men with cardiac, pulmonary, or peripheral vascular disease versus 69% overall. When non-responders were re-invited or given the opportunity to revise appointment times, the overall attendance rate rose indicating that convenience of screening influences attendance. In MASS, advanced age was also associated with a small but significant decrease in attendance rates and an increase in AAA prevalence.^48^ A socioeconomic deprivation score derived from census data also had a strong association with attendance. The attendance rate in the quartile with the lowest socioeconomic status was 75% compared to 85% in the quartile with the highest status (OR 0.44; 95% CI, 0.41–0.48). Lower socioeconomic status was also associated with an increased prevalence of AAAs in those scanned (OR 1.38 for the lowest vs. highest quartile; 95% CI, 1.16–1.63).

## Key Question 1b. For individuals who do not have AAAs on initial screening, does periodic repeat screening reduce AAA-related adverse health outcomes?

Death from AAA rupture after a single negative ultrasound scan at 65 years of age is an infrequent occurrence. As part of a population screening program in Gloucestershire, UK, all men are offered ultrasonography at age 65.^58^ A cohort of 223 65-year-old men with no AAAs on initial ultrasound had repeat ultrasounds at 5 and 12 years. Eight men were lost to follow-up, and 86 men died of causes unrelated to AAAs. None of the remaining 129 men experienced a clinically significant increase in aortic diameter over 12 years. Chichester study investigators prospectively followed 1011 men with aortic diameters < 3.0 cm on initial screening at age 65 years.^16^ Over 10 years of follow-up, the incident rate for new AAAs was 4%. None of the new AAAs identified exceeded 4.0 cm in diameter. Other studies from the UK and from the VA ADAM study reported similar findings over shorter time intervals.^59,^ ^60^ Based on these studies, a single negative ultrasonography exam at age 65 appears to virtually exclude future risks of AAA rupture or death.

## Key Question 2. What are the harms associated with AAA screening?

No significant physical harms appear to arise from ultrasound screening for AAA.^57^ Table 6 addresses psychological harms that may result from AAA screening. As part of the MASS screening trial, a survey was mailed six weeks after screening to a sub sample of 599 of 25 485 (2.1%) participants with no aneurysm found on screening, and 631 of 1333 (47.3%) participants found to have aortic aneurysms ≥ 3.0 cm.^11^ Responses to mailed surveys were 90% in both groups. Those participants with positive scans initially had slightly more anxiety, lower SF-36 mental physical health scores, and lower self-rated health status than those with negative scans; however, these differences were no longer apparent after six weeks. In all cases, however, results fell within population norms.

Table 6. Harms of AAA Screening and Treatment

Study | Population, n (% Response) | Measurements | Results
MASS Ashton, 2002^11^ | 6 weeks after screening | SF-36, HADS, Short-form state anxiety scale of the Spielberger state-trait anxiety scale, EuroQol EQ-5D | Those with a positive screen, compared to those with negative screens, had slightly higher anxiety scores (P=0.02) but no difference in depression scores (P=0.09) at 6 weeks after screening. Those with a positive screen also had showed lower scores on SF-36 mental (P=0.003) and physical (P=0.003) scales. Self-rated health was also lower in those with a positive screen (P=0.0003). In all cases, results for both groups within population norms. Results in control population were not reported.
| Positive n=599 (90%)
| Negative n=631 (90%)
| Control n=726 (77%)
| Total 555 with positive screen at 3 and 12 months after aneurysm detection or surgery | Same | Those undergoing surgery, compared to surveillance, scored lower on the SF-36 mental health scale at 3 months (P=0.004), but not at 12 months. Surgery was associated with better self-rated health at 3 and 12 months (P=0.0003, P=0.0007 respectively. No significant differences on other measures.
| Surveillance n=426
| Surgery n=129)
VIBORG Lindholt, 2000^61^ | Control n=231 (66%) | ScreenQL | Those with positive screen significantly lower in health and over-all score. Scores were significantly lower in attendees pre-scan vs post-scan. Those under surveillance had significantly lower scores than those having immediate surgery No differences after surgery.
| At screening n=271 (81%)
| 1 month post screen n=286 (85%)
| With AAA n=127 (85%)
| Surgery after surveillance n=29 (81%)
ADAM Lederle, 2003^71^ | 1,136 patients at 16 VA Medical Centers with AAAs 4.0–5.4 cm were randomized to immediate surgical repair or surveillance and followed up for 3.5 to 8 years (mean, 4.9 years). | SF-36 | The two randomized groups did not differ significantly for most SF-36 scales at most times, but the immediate repair group scored higher overall in general health (P <.0001), which was particularly evident in the first 2 years after randomization, and slightly lower in vitality (P <.05). The baseline value of one SF-36 scale, physical functioning, was an independent predictor of mortality. Overall, more patients became impotent after randomization to immediate repair compared with surveillance (P <.03), but this difference did not become apparent until more than 1 year after randomization. Maximum activity level did not differ significantly between the two randomized groups, but decline over time was significantly greater in the immediate repair group (P <.02).
Lucarotti 1997^62^ | 161 men attending routine aneurysm screening in the Gloucestershire Aneurysm Screening Programme. 100 men with negative scans compared to 61 men with positive scans. One hundred men had a normal aorta and 61 were identified as having aneurysms. | GHQ-General Health Questionnaire; linear analogue anxiety scale | Tests administered just before screening and 1 month later. There was no difference in anxiety levels between those men with normal aortas and those with aneurysms either before or after screening. There was a statistically significant reduction in anxiety for both these groups 1 month after screening.

ADAM, VA Aneurysm Detection and Management (ADAM) Screening Study; HADS, Hospital Anxiety and Depression Scale;

MASS, Multicentre Aneurysm Screening Study; SF-36, is a mental health survey questionnaire; VA, Veterans Affairs.

In the Viborg trial, a retrospective study was performed based on surveys of those attending ultrasound scanning, those invited but not attending, and uninvited controls.^61^ One month after screening, participants with AAA ≥ 3.0 cm showed small but significant decreases on the survey measures of general health perception and self-estimated quality of life compared to non-invited controls. No differences were observed on other subscales measuring emotional health, psychosomatic distress, social and family, and marriage roles. Those attending screening who were not found to have AAAs, compared to those invited but not attending had significantly lower scores initially on measures of emotional health, psychosomatic distress, and self-estimated quality of life. One month after screening, however, these differences were no longer present, and scores on psychosomatic distress and self-estimated quality of life were significantly better in attendees versus non-attendees. These findings may reflect anxiety about attending screening or relief when no AAA was identified.

In a prospective case-control study of 161 participants from the Gloucestershire, UK aneurysm screening program, no initial differences in anxiety levels were found between men with normal aortas and those with aneurysms either before of after scanning.^62^ Both groups, however, showed significant reductions in anxiety one month after screening.

## Key Question 3. For 3.0–5.4 cm AAAs detected through screening, does immediate repair or surveillance reduce AAA-related adverse health outcomes?

Immediate repair of 3.0–3.9 cm AAAs is generally not considered since they rarely rupture, although periodic surveillance is a recommended practice.^26,^ ^33,^ ^34,^ ^63^

Management of 4.0–5.4 cm AAAs has been more controversial. At one time, vascular surgeons recommended elective repair of AAAs ≥ 4.0 cm in those with no medical contraindications.^64^ The rationale underlying this recommendation was that patients undergoing early elective surgical repair of moderate-sized 4.0 to 5.4 cm AAAs will be younger and may have lower mortality rates and fewer surgical complications than if surgery were delayed until the AAA expanded to ≥ 5.5 cm. Patients may prefer this approach rather than face a small but definite risk of rupture with delayed repair.

On the other hand, elective AAA repair may be associated with operative mortality rates of 1–5% in referral centers and 4–8% in community settings.^65^ On that basis, others recommended periodic surveillance with delayed surgical repair for AAAs that expanded over time to 5.0–6.0 cm.^26,^ ^27,^ ^66^ To address this controversy, two randomized controlled trials were conducted comparing immediate surgical repair to periodic surveillance for 4.0–5.4 cm (Table 7).^31,^ ^32,^ ^67^

Table 7. Studies Comparing Surveillance vs Immediate Repair of 4.0–5.4 cm Abdominal Aortic Aneurysms

| UKSAT | | ADAM
Reference | UK Small Aneurysm Trial Participants, 2002^67^ | | Lederle, 2002^31^
Population
Age, Years | 60–76 (mean 69.3 years) | | 50–79 (mean 68.1 years)
Male | 82.80% | | 99.2%
Location | 93 UK Hospitals | | 16 Veteran Affairs (VA) Medical Centers
Interventions
Surveillance | Repeat imaging every 6 months for diameters between 4.0–5.0 cm and every 3 months for 5.0–5.5 cm. | | Repeat imaging every 6 months, repair upon reaching 5.5 cm, enlarged by at least 0.7 cm in 6 months or at least 1.0 cm in 1 year, or until symptomatic
Immediate Repair | Repair within 3 months | | Repair within 6 weeks
Follow-up Period | 8 years | | 8 years
Recruitment | 1,276 by referral or from screening | | 126,196 in multi-center VA screening program
Randomized | 1090 | | 1136
Quality Rating | Good | | Good
Results | [underlined: Immediate Repair] | [underlined: Surveillance] | [underlined: Immediate Repair] | [underlined: Surveillance]
N | 563 | 527 | 569 | 567
Prevalence
4.0–4.4 cm | 214 | 213 | 174 | 197
4.5–4.9 cm | 175 | 169 | 205 | 188
5.0–5.4 cm | 174 | 145 | 190 | 182
Mortality Follow-up | 100% | 100% | 85.3% | 100%
Completed Surveillance Protocol | | 93% | | 87.0%
Elective/Emergency Repairs | 526 (93%) | 389 (74%) | 527 (93%) | 349 (62%)
30-day Surgical Mortality | 5.5% | 7.2% | 2.6% | 2.0%
Ruptured AAA | 1.8% | 4.0% | 0.4% | 1.9%
AAA-related mortality | 37 | 49 | 19 | 19
OR* (95% CI) | 0.69 (0.44–1.07) | | 1.0 (0.52–1.90)
All-cause mortality | 159 | 150 | 143 | 122
OR* (95% CI) | 0.83 (0.69–1.00) | | 1.22 (0.93–1.61)
HARMS | [underlined: Immediate Repair] | [underlined: Surveillance] | [underlined: Immediate Repair] | [underlined: Surveillance]
Re-operation Required | - | - | 9 | 4
Myocardial Infarction | - | - | 5 | 13
Amputation | - | - | 2 | 2
Paraplegia | - | - | 0 | 2
Stroke | - | - | 3 | 2
Pulmonary Embolism | - | - | 4 | 1
Dialysis | - | - | 1 | 2
Late Graft Failure | - | - | 2 | 1
Re-hospitalization | - | - | 108 | 56
Any complication | - | - | 275 | 193

ADAM, VA Aneurysm Detection and Management Screening Study; CI, confidence interval; OR, odds ratio; UKSAT, UK Small Aneurysm Trial Participants.

* Odds ratios were obtained from the random effects meta-analyses based on unadjusted data for each trial.

The characteristics and outcomes of these trials are shown in Table 7. The ADAM (ADAM) study was a multi-center trial conducted in 16 Veterans Affairs Medical Centers of 1136 veterans with 4.0–5.4 cm AAAs of whom 569 were randomized to immediate surgical repair and 567 to periodic surveillance with repair for AAAs expanding to ≥ 5.5 cm.^31^ In the UK Small Aneurysm Trial (UKSAT), 563 individuals with 4.0–5.4 cm AAAs were randomized to immediate surgical repair and 527 individuals to periodic surveillance with delayed repair.^32,^ ^67^ The quality of both trials was rated “Good” based on USPSTF quality rating methods.^40^

After eight years of follow-up, neither trial found a significant difference in AAA-related mortality between immediate repair and surveillance patients. Most patients undergoing periodic surveillance in both trials eventually had surgery based on aneurysm expansion (UKSAT 74%; ADAM 62%). The summary odds ratio from the meta-analysis of AAA-related mortality based on unadjusted data for the two trials was 0.77 (95% CI, 0.54–1.12) (Figure 5).

Figure 5. Meta-Analysis of AAA-related Mortality in Small Aneurysm Trials

In the ADAM trial, no difference was found in all-cause mortality for immediate repair compared to surveillance. In the UKSAT trial, the hazard ratio for all-cause mortality was 0.83 (95% CI, 0.69–1.00) after adjustment for age, sex, smoking status, and other factors. This result was not attributable to fewer AAA-related deaths, but may have arisen from lifestyle changes in the immediate repair group, such as smoking cessation after surgery. Survival analyses, however, showed no evidence that patients in the immediate repair group had more life-years gained compared to those undergoing surveillance. The summary odds ratio from the meta-analysis of all-cause mortality combining unadjusted data for the two trials was 0.97 (95% CI, 0.81–1.16) (Figure 6).

Figure 6. Meta-Analysis of All-Cause Mortality in Small Aneurysm Trials

## Key Question 4. What are the harms associated with repair of AAAs ≥ 5.5 cm?

Harms reported from AAA repair in the major screening trials have already been discussed. Known postoperative complications of elective aneurysm repair include myocardial infarction, respiratory failure, renal failure, ischemic colitis, and spinal cord ischemia. Prosthetic graft infections may also occur but are recognized much later. Reports of both morbidity and mortality rates after AAA repair, however, vary based on the study design.^68^ Prospective population and hospital studies generally yield higher rates of complications than retrospective hospital studies. Cardiac complications are the most common with rates ranging from 10.6–11% in prospective population and hospital studies.

A retrospective analysis using data from the Nationwide Inpatient Sample database, a 20% sample of discharge data from all nonfederal US hospitals, examined mortality and complication rates for 16 450 intact AAA repairs from 1994 to 1996.^69^ The overall in-hospital mortality rate was 4.2%, with a complication rate of 32.4%. Compared to younger age groups, the OR for in-hospital mortality was 1.8 (95% CI 1.4–2.3) in patients aged 70–79, and 3.8 (95% CI 2.9–4.9) in patients aged over 79 years. Increased in-hospital mortality was also associated with female gender (OR 1.6; 95% CI 1.3–1.9); preoperative renal failure (OR 9.5; 95% CI 7.7–11.7); and more than three preoperative comorbidities (OR 11.2; 95% CI 3.6–35.4).

In other retrospective analyses from the same database, significant variations for in-hospital mortality were associated with surgical specialty, surgeon volume, and hospital volume.^70^ The lowest mortality rates were for AAA repairs performed by experienced vascular surgeons in hospitals with a high volume of AAA repair.

## Key Question 5. What are the harms associated with immediate repair or surveillance of 3.0–5.4 cm AAAs?

We found no studies that specifically addressed psychological harms from surveillance for 3.0–3.9 cm AAAs. Table 7 summarizes physical harms of immediate repair compared to surveillance for 4.0–5.4 cm from the ADAM study. Compared to the immediate repair group, the surveillance group only had a significantly increase risk of myocardial infarction. The total number of AAA-related hospitalizations was significantly lower in the surveillance group. Table 6 summarizes findings from the ADAM trial on psychological and functional harms of immediate repair versus surveillance.^71^ The two randomized groups did not differ significantly for most Medical Outcomes Study short-form scales. The immediate repair group had higher scores for the general health subscale (P < 0.0001). Overall, more patients became impotent after randomization to immediate repair compared with surveillance (P < 0.03), but this difference did not become apparent until more than one year after randomization. Maximum activity level did not differ significantly between the two groups at randomization, but decline over time was significantly greater in the immediate repair group (P < 0.02).

The UKSAT trial also used the Medical Outcomes Study short-form to analyze health-related quality of life for all 1090 study participants.^72^ At baseline, reported measures of functional status and health were similar for the immediate repair and surveillance groups. After 12 months, patients in the immediate repair group reported significant improvement in perception of general health and lower bodily pain scores compared to the surveillance group.

### Endovascular Aneurysm Repair

Endovascular repair of abdominal aortic aneurysms (EVAR) was first attempted in 1991.^73^ The impetus for developing this procedure was the expectation that EVAR, as a less invasive procedure than open repair, may reduce procedural morbidity and mortality, speed recovery, decrease use of hospital resources, and reduce costs of AAA repair.^74^ Over the last decade, at least 16 different devices have been tested, and as of 2004, the US Food and Drug Administration (FDA) has approved four devices, although one of these has been withdrawn.

We searched the literature from 1994 to 2004 for randomized clinical trials comparing EVAR with open aneurysm repair. The majority of trials identified were non-randomized Phase I or Phase II clinical trials, with either no controls or with matched controls undergoing open repair. Many of these trials were conducted to test investigational devices in support applications for FDA approval. Through our literature search and contacts with experts, we identified five randomized trials ongoing as of July 2004 that compare EVAR with open repair (Table 8).^75,^ ^76^ All trials include patients with AAAs ≥ 5.0–5.5 cm on ultrasound or computed tomography scanning. Most use all-cause mortality as the primary endpoint. Publications of main results from these trials are expected in the next several years.

Table 8. Ongoing Studies of Endovascular Repair of Abdominal Aortic Aneurysms (EVAR)

| DREAM | Open vs Endovascular Repair Trial (OVER) | EVAR 1 | EVAR 2 | Anévrisme de l'aorte abdominale: Chirurgie versus Endoprothèse (ACE)
Reference | Prinssen, 2002^75^ | Unpublished, Lederle | Brown, 2004^76^ | | Unpublished
Location | Holland | U.S. | UK | UK | France
Protocol | EVAR or open repair | EVAR or open repair | EVAR or open repair | EVAR with best medical management or best medical management | Not able to obtain any further information
Centers | Required to have performed >20 EVAR, may refer to another center for procedure | 40 VA sites that are prepared to perform open and EVAR with at least one approved device | Required to have performed > 20 EVAR procedures | Required to have performed > 20 EVAR procedures
EVAR Device | European Conformité Européenne-Mark Approval or preliminary Market Approval or investigational device exemption of the FDA | Any FDA approved device, including any new devices approved during study | In-house devices or commercially available devices with CE mark, which is favored | In-house devices or commercially available devices with CE mark, which is favored
Inclusion Criteria | Asymptomatic AAA > 5.0 cm, adequate infrarenal neck, life expectation > 2 years, cleared for transabdominal intervention | AAA ≥ 5.0 cm or ≥ 4.5 cm if expanded more than 0.7 cm in 6 months or 1.0 cm in 1 year, eligible for either procedure | ≥ 60 yrs, ≥ 5.5 cm, ≥ 5.0 cm ultrasound referred for CT scan due to under sizing with U/S, anatomical suitability for EVAR, fitness for surgery | ≥ 60 years, ≥ 5.5 cm, ≥ 5.0 cm ultrasound referred for CT scan due to under sizing with ultrasound, anatomical suitability for EVAR
Exclusion Criteria | Juxtarenal or suprarenal AAA, inflammatory AAA, infrarenal neck unsuitable for EVAR, active infection, transplantation patients, non-iatrogenic bleeding diathesis, connective tissue disease | Previous AAA surgery, urgent need for surgery, or evidence of AAA rupture | Myocardial infarction (MI) or angina onset within last 3 months, unstable angina, severe valve disease, significant arrhythmia, uncontrolled CHF, Severe COPD, Renal Failure FEV1 < 1.0 L | MI within last 3 months, onset of angina within last 3 months, unstable angina at night or at rest
Randomization | Stratified by center to either open or EVAR | Equal chance of open or EVAR | Stratified by center to either open or EVAR | Stratified by center to either open or EVAR
Sample Size | 400; 200 in each arm. Based on a 10% reduction in mortality and morbidity with a statistical power of 80% | 1260; 85% power to detect a 25% difference in mortality. | 900 in EVAR Trial 1, with 80% power to detect a reduction in 2.5% mortality for EVAR | 280 patients in EVAR Trial 2 with 93% power to detect a difference of 10% between the two treatment regimes
Primary Outcome | Combined perioperative mortality and morbidity | All-cause mortality | All-cause mortality | All-cause mortality
Secondary Measures | QoL with SF-36, EQ-5D, and questionnaire about sexual function, cost-effectiveness | Morbidity, secondary procedures, cost, health-related quality of life | QoL through SF-36, EQ-5D, State-trait Anxiety questionnaire, and the patient generated index; cost-effectiveness of EVAR vs open repair quality-adjusted life-years (QALY) | QoL through SF-36, EQ-5D, State-trait Anxiety questionnaire, and the patient generated index. Cost-effectiveness of best medical management versus EVAR plus best medical management (QALY)
Adverse Events | Complications of remote/systemic and local/vascular | Operative AAA mortality and all AAA repair complications | Tender AAA, ruptured AAA, conversion to open repair, MI, stroke, renal failure and amputation, growth rates, endoleaks | Tender AAA, ruptured AAA, conversion to open repair, MI, stroke, renal failure and amputation, growth rates, endoleaks
Duration | 2 years of follow-up | 8 years of follow-up | 3.33 years/patient | 3.33 years/patient
Results Anticipated | Early 2004 | 12 month data for all participants-early 2007, complete results 2010 | Mid 2005 | Mid 2005

CHF, congested heart failure; CT, computed tomography; FDA, Food and Drug Administration;MI, myocardial infarction; QALY, quality-adjusted life-years; QoL, quality of life; VA, Veterans Affairs.

We also identified three multi-center registries that are prospectively following patents undergoing EVAR in participating clinical centers: The European EUROSTAR Registry, established in 1996^77^; the UK RETA registry, established in 1996^78^; and the US Lifeline Registry, established in 2001.^79^

One multi-center clinical trial recently reported 30-day mortality rates for 1047 patients age 60 years or older with intact AAAs ≥ 5.5 cm, who were deemed fit for surgery, randomized to EVAR or open surgical repair between September, 1999 and December, 2003.^80^ The 30-day mortality rate was 1.7% for 531 patients randomized to EVAR compared to 4.7% for 516 patients assigned to open repair (OR 0.35; 95% CI, 0.16–0.77).

Short-term mortality rates for EVAR from reviews of uncontrolled trials and registry data range from 1.3% to 3.6%.^69,^ ^74,^ ^81–83^ The EVAR 1 trial, however, included only those patients deemed fit for surgery from a larger group of patients with AAAs judged to be anatomically suitable for EVAR. Registry and early trial data include patients who may have been unfit for open repair based on the EVAR 1 inclusion criteria. Patients from the EVAR trial who were unfit for surgery were recruited to participate in a parallel EVAR 2 randomized trial.^76^

EVAR is associated with both short-term and long-term adverse events. In a report from the EUROSTAR registry, 27 of 1554 (2%) required immediate conversion to open repair; and 279 of 1554 patients (18%) experienced systemic cardiac, pulmonary, renal, cerebral, or infectious complications following EVAR,^84^ compared to reported rates of 32% for similar complications following open repair of intact AAAs.^69^ Long-term adverse events following EVAR may arise from device failure, which could cause bleeding into the aneurysmal sac either around the device, or from retrograde flow into the aneurysmal sac through collateral blood vessels. These adverse events may require late conversion to open repair or aneurysmal rupture. In a report on four years of data from the EUROSTAR registry, conversion to open repair occurred at an average annual rate of 2.1% and was associated with a 24.4% 30-day operative mortality rate.^85^

### Recommendations of Other Groups

In 2004, the Society for Vascular Surgery (SVS) recommended baseline ultrasound screening for AAA patients deemed fit for interventions among all men aged 60 to 85 years, women aged 60 to 85 years with cardiovascular risk factors, and men and women older than 50 years with a family history of AAA.^63^ The SVS had previously recommended elective repair for AAA ≥ 5.5 cm for the average patient.^65^ For patients with smaller AAAs, they recommend no further testing for aortic diameter less than 3.0 cm; annual ultrasound examinations for 3–3.9 cm AAAs; biannual examinations for 4.0 to 4.5 cm AAAs; and referral to a vascular specialist for AAA greater than 4.5 cm in diameter.

In 1994, the Canadian Preventive Services cited a lack of evidence for or against a recommendation to screen for AAA using ultrasound. This recommendation, like the 1996 USPSTF recommendation, preceded publication of the population-based screening studies reviewed here.