# Methods

## Analytic Framework and Key Questions

The analytic framework shown in Figure 1 was developed to guide our literature search strategy. We examined five key questions:

Figure 1. Primary Care Screening for Abdominal Aortic Aneurysm: Analytic Framework

1. a) Does AAA screening, in an asymptomatic average-risk or high-risk population, reduce AAA-related adverse health outcomes? b) For individuals who do not have AAAs on initial screening, does periodic repeat screening reduce AAA-related adverse health outcomes?
2. What are the harms associated with AAA screening?
3. For 3.0–5.4 cm AAAs detected through screening, does immediate repair or surveillance reduce AAA-related adverse health outcomes?
4. What are the harms associated with repair of AAAs ≥ 5.5 cm?
5. What are the harms associated with immediate repair or surveillance of 3.0–5.4 cm AAAs?

We focused our review of screening on the use of abdominal ultrasound scanning to detect AAAs in asymptomatic patients. The sensitivity of ultrasound scanning for an AAA is 95%, the specificity approaches 100%, and the examination is reliable and reproducible.^34^ Limited ultrasonography for AAA screening can be performed in less than ten minutes, including time for training and unused appointments.^10^

Physical examination may also detect AAAs, particularly those large enough to warrant surgery. Physical examination may not be a suitable for population screening due to high false-positive and false-negative rates.^38,^ ^39^ Other imaging modalities, such as computed tomography and magnetic resonance imaging, are also accurate and reliable for assessing aortic size, but are not as accessible as ultrasound imaging.^34^ We found no population-based trials of AAA-screening using physical examination or imaging methods other than ultrasound scanning.

### Literature Search Strategy

We searched MEDLINE® from January 1994 to May 2004 to identify studies about the following: the effectiveness of AAA screening in population-based settings, the effectiveness of repeat AAA screening, screening harms, effective management strategies for AAAs 3.0–5.4 cm, and harms of treatment for AAAs 3.0–5.4 cm and AAAs ≥ 5.5 cm. Search strategies for each key question are detailed in Appendix 1.

We included only data published in full-article form. We also searched the online Cochrane Database of Systematic Reviews and Cochrane Controlled Trials Register. Additionally, we obtained articles from the reference lists of pertinent studies and reviews and from expert recommendations.

### Inclusion/Exclusion Criteria

Two reviewers (Fleming and Beil) individually reviewed each abstract using the inclusion/exclusion criteria listed in Appendix 2. Excluded studies are listed in Appendix 3. For key question 1a, only randomized population-based trials of screening with unscreened controls were included. To evaluate the benefit of periodic repeated screening after a normal scan (key question 1b), we identified cohort or follow-up studies of patients without AAAs identified in population screening studies. For key question 3, only randomized clinical trials of immediate repair or ultrasound surveillance for AAAs 3.0–5.4 cm were included. For key questions related to harms of screening and treatment, we included studies of harms from randomized controlled trials, or retrospective or prospective cohort studies with comparative data. We resolved disagreements on inclusion/exclusion of individual studies by consensus by obtaining the source article and examining its relevance to the key question.

### Data Extraction and Synthesis

We assessed the quality of included studies based on published USPSTF criteria (Appendix 4).^40^ For each study rated “Good” or “Fair” quality, we abstracted study design, setting, population demographics, and results for primary and secondary outcomes.

To assess the benefit of population-based AAA screening, and immediate repair versus surveillance for moderate-sized AAAs, we pooled eligible studies to estimate the likelihood that screening reduces AAA-related death and all-cause mortality. We calculated estimates of unadjusted odds ratios with 95% confidence intervals. We assessed heterogeneity by using graphs of the outcomes and the Mantel–Haenszel chi-square test. We performed meta-analyses to calculate summary estimates for AAA-related mortality and all-cause mortality using the DerSimonian and Laird random-effects model.^41^ We deemed the random-effects model to be more appropriate than a fixed-effects model because the included studies differed in characteristics such as population, starting and stopping ages for screening, outcomes ascertainment, and duration of follow-up.^42^ Statistical analyses were performed with RevMan software.^43^

We used these pooled estimates to model the impact of AAA screening in a hypothetical population. These analyses also incorporated the rates of other AAA-related events obtained by averaging rates across all trials. We modeled upper and lower bounds for outcomes using the 95% confidence intervals from the meta-analyses and the average rates of other events.