# Acknowledgments

This Evidence Synthesis was funded by the Agency for Healthcare Research and Quality (AHRQ) for the U.S. Preventive Services Task Force (USPSTF), and the investigators acknowledge the contributions of Gurvaneet Randhawa, MD, MPH, Task Order and Medical Officer, AHRQ, and Therese Miller, DrPH, Task Order Officer, AHRQ. Members of the USPSTF who served as leads for this project include: Ned Calonge, MD, MPH; Russell Harris, MD, MPH; Mark S. Johnson, MD, MPH; Diana B. Petitti, MD, MPH; and Steven M. Teutsch, MD, MPH. Additional members of the Oregon EPC project team include Daphne Plaut, MLS, research librarian. Lastly, the authors would like to thank David Ballard, MD, PhD and the other reviewers for their contributions to this project.

## Request for Reprints

Reprints are available from the AHRQ Web site at www.ahrq.gov (click on Preventive Services) and in print through the AHRQ Publications Clearinghouse (call 1-800-358-9295).