# Appendix C: Excluded Studies

Study Identification | Reason for Exclusion
Bergea B, Lennart B, Svedbergh B. Primary argon laser trabeculoplasty vs pilocarpine: III. Long-term effects on visual fields. Acta Ophthalmologica Scandinavica 1995; 73(3):207–215. | Study Quality: Analysis not based on intention-to-treat: 6/82 subjects excluded from analysis because of withdrawal or inadequate follow-up.
Bergea B, Bodin L, Svedbergh B. Primary argon laser trabeculoplasty vs pilocarpine. IV. Long-term effects on optic nerve head. Acta Ophthalmologica Scandinavica 1995; 73(3):216–221.
Heijl A, Bengtsson B. Long-term effects of timolol therapy in ocular hypertension: a double-masked, randomised trial. Graefe's Archive for Clinical and Experimental Ophthalmology, 2000;238:877–883. | Study Quality: Analysis not based on intent-to-treat; large attrition rate.
Kaiser HJ, Flammer J, Stumpfig D, Hendrickson P. Long-term visual field follow-up of glaucoma patients treated with beta-blockers. Survey of Ophthalmology.1994; 38 Suppl:S156–S159. | Study Quality: Analysis not based on intent-to-treat; large attrition rate (34%).
Koseki N, Araie M, Yamagami J, Shirato S, Yamamoto S. Effects of oral brovincamine on visual field damage in patients with normal-tension glaucoma with low-normal intraocular pressure. Journal of Glaucoma 1999; 8:117–123. | Study Quality: Analysis was not based on intent-to-treat. Four subjects who withdrew because of medication side effects were excluded from analysis. Japanese study. Intervention medication not available in US.
Migdal C, Walter G, Hitchings R. Long-term functional outcome after early surgery compared with laser and medicine in open-angle glaucoma. Ophthalmology 1994; 101:1651–1657. | Study Quality: Analysis not based on intent-to-treat. Patients were excluded from analysis of outcomes if initially assigned treatment (medication, laser, ALT) failed to lower IOP to < 22 mm Hg.
Stewart WC, Sine CS, LoPresto C. Surgical vs medical management of chronic open-angle glaucoma. American Journal of Ophthalmology 1996; 122:767–774. | Study Type: Not RCT: matched-pairs study design.
Watson PG, Barnett MF, Parker V, Haybittle J. A 7 year prospective comparative study of three topical beta blockers in the management of primary open angle glaucoma. British Journal of Ophthalmology 2001; 85:962–968. | Study Quality: 53% attrition rate by 12 mo

ALT, argon laser trabeculoplasty; IOP, intraocular pressure; RCT, randomized controlled trial.