# Appendix B: Inclusion/Exclusion Criteria

Key Question 1 | - Randomized clinical trials (good or fair quality); - Unselected population, relevant to primary care; - Mass screening; - Health outcome
Key Question 3,7 | - Unselected population, relevant to primary care; - Gold standard as control; - Feasible new screening test
Key Questions 4,5,6,8 | - Randomized clinical trials (good or fair quality); - Health outcome; - If no randomized controlled trials, extend to observational studies and case-control studies; - Follow up > 2 yr