# Appendix A: Search Strategy: MEDLINE® 1994 through January, 2004

RTI-UNC EPC Search 1

1 exp glaucoma
2 exp glaucoma, open-angle
3 exp intraocular pressure
4 exp ocular hypertension
5 exp laser surgery
6 exp therapeutics
7 exp treatment outcome
8 exp visual fields
9 exp visual acuity
10 randomized controlled trial.pt. or exp randomized controlled trials/ or exp random allocation/ or exp double blind method/ or single blind method
11 exp meta-analysis/ or meta-analysis.pt.
12 10 or 11
13 1 or 2 or 3 or 4
14 limit 13 to (human and english language and yr=2001-2004)
15 5 or 6 or 7
16 12 and 14 and 15

RTI-UNC EPC Search 2

1 exp Therapeutics/ or treatment.mp.
2 exp Intraocular Pressure
3 exp Glaucoma, Open-Angle
4 randomized controlled trial.pt. or exp randomized controlled trials/ or exp random allocation/ or exp double blind method/ or single blind method
5 exp Pharmaceutical Preparations
6 exp Ocular Hypertension
7 2 or 6
8 limit 7 to (human and english language and yr=2001-2004)
9 1 or 5
10 8 and 9 and 3
11 10 and 4