# References

1 Quigley HA, Vitale S. Models of open-angle glaucoma prevalence and incidence in the United States. Investigative Ophthalmology & Visual Science. 1997;38(1):83-91. [pmid: 9008633].
2 Tielsch JM, Sommer A, Katz J, Royall RM, Quigley HA, Javitt J. Racial variations in the prevalence of primary open-angle glaucoma. The Baltimore Eye Survey. JAMA. 1991;266(3):369-374. [pmid: 2056646].
3 Mitchell P, Smith W, Attebo K, Healey PR. Prevalence of open-angle glaucoma in Australia. The Blue Mountains Eye Study. Ophthalmology. 1996;103(10):1661-1669. [pmid: 8874440].
4 Quigley HA. Open-angle glaucoma. New England Journal of Medicine. 1993;328(15):1097-1106. [pmid: 8455668].
5 Sommer A, Tielsch JM, Katz J, Quigley HA, Gottsch JD, Javitt J, et al. Relationship between intraocular pressure and primary open angle glaucoma among white and black Americans. The Baltimore Eye Survey. Archives of Ophthalmology. 1991;109(8):1090-1095. [pmid: 1867550].
6 Leske MC, Connell AM, Wu SY, Nemesure B, Li X, Schachat A, et al. Incidence of open-angle glaucoma: the Barbados Eye Studies. The Barbados Eye Studies Group. Archives of Ophthalmology. 2001;119(1):89-95. [pmid: 11146731].
7 Tielsch JM, Katz J, Singh K, Quigley HA, Gottsch JD, Javitt J, et al. A population-based evaluation of glaucoma screening: the Baltimore Eye Survey. American Journal of Epidemiology. 1991;134(10):1102-1110. [pmid: 1746520].
8 Tielsch JM, Katz J, Sommer A, Quigley HA, Javitt JC. Family history and risk of primary open angle glaucoma. The Baltimore Eye Survey. Archives of Ophthalmology. 1994;112(1):69-73. [pmid: 8285897].
9 American Academy of Ophthalmology. Preferred Practice Pattern. Primary Open-Angle Glaucoma. Limited revision ed. 2003.
10 Jay JL, Murdoch JR. The rate of visual field loss in untreated primary open angle glaucoma. British Journal of Ophthalmology. 1993;77(3):176-178. [pmid: 8457511].
11 Quigley HA, Tielsch JM, Katz J, Sommer A. Rate of progression in open-angle glaucoma estimated from cross-sectional prevalence of visual field damage. American Journal of Ophthalmology. 1996;122(3):355-363. [pmid: 8794708].
12 Heijl A, Leske MC, Bengtsson B, Hyman L, Bengtsson B, Hussein M, et al. Reduction of intraocular pressure and glaucoma progression: results from the Early Manifest Glaucoma Trial. Archives of Ophthalmology. 2002;120(10):1268-1279. [pmid: 12365904].
13 Lichter PR, Musch DC, Gillespie BW, Guire KE, Janz NK, Wren PA, et al. Interim clinical outcomes in the Collaborative Initial Glaucoma Treatment Study comparing initial treatment randomized to medications or surgery. Ophthalmology. 2001;108(11):1943-1953. [pmid: 11713061].
14 The Glaucoma Laser Trial (GLT). 6. Treatment group differences in visual field changes. Glaucoma Laser Trial Research Group. American Journal of Ophthalmology. 1995;120(1):10-22. [pmid: 7611312].
15 U.S. Preventive Services Task Force. Screening for Glaucoma. In: DiGuiseppi C, Atkins D, Woolf SH, Kamerow DB, editors. Guide to Clinical Preventive Services. Washington, DC: Office of Disease Prevention and Health Promotion, 1996: 383–391.
16 Harris RP, Helfand M, Woolf SH, Lohr KN, Mulrow CD, Teutsch SM, et al. Current methods of the US Preventive Services Task Force: a review of the process. American Journal of Preventive Medicine. 2001;20(3:Suppl):21-35. [pmid: 11306229].
17 Kamal D, Hitchings R. Normal tension glaucoma—a practical approach. British Journal of Ophthalmology. 1998;82(7):835-840. [pmid: 9924383].
18 Quigley HA, Katz J, Derick RJ, Gilbert D, Sommer A. An evaluation of optic disc and nerve fiber layer examinations in monitoring progression of early glaucoma damage. Ophthalmology. 1992;99(1):19-28. [pmid: 1741133].
19 Coleman AL, Sommer A, Enger C, Knopf HL, Stamper RL, Minckler DS. Interobserver and intraobserver variability in the detection of glaucomatous progression of the optic disc. Journal of Glaucoma. 1996;5(6):384-389. [pmid: 8946294].
20 Harper R, Henson D, Reeves BC. Appraising evaluations of screening/diagnostic tests: the importance of the study populations. British Journal of Ophthalmology. 2000;84(10):1198-1202. [pmid: 11004111].
21 Kass MA, Heuer DK, Higginbotham EJ, Johnson CA, Keltner JL, Miller JP, et al. The Ocular Hypertension Treatment Study: a randomized trial determines that topical ocular hypotensive medication delays or prevents the onset of primary open-angle glaucoma. Archives of Ophthalmology. 2002;120(6):701-713. [pmid: 12049574].
22 Ellish NJ, Higginbotham EJ. Evaluating a visual field screening test for glaucoma: how the choice of the gold standard affects the validity of the test. Ophthalmic Epidemiol. 2001;8(5):297-307. [pmid: 11922383].
23 Sponsel WE, Ritch R, Stamper R, Higginbotham EJ, Anderson DR, Wilson MR, et al. Prevent Blindness America visual field screening study. The Prevent Blindness America Glaucoma Advisory Committee. American Journal of Ophthalmology. 1995;120(6):699-708. [pmid: 8540543].
24 Wilson MR. Screening paradigms in glaucoma. Journal of Glaucoma. 2001;10(5:Suppl 1):S25-S27. [pmid: 11890267].
25 Patel SC, Friedman DS, Varadkar P, Robin AL. Algorithm for interpreting the results of frequency doubling perimetry. American Journal of Ophthalmology. 2000;129(3):323-327. [pmid: 10704547].
26 Coleman AL. Glaucoma. Lancet. 1999;354(9192):1803-1810. [pmid: 10577657].
27 American Academy of Ophthalmology. Comprehensive adult medical eye evaluation. 2000.
28 Grodum K, Heijl A, Bengtsson B. A comparison of glaucoma patients identified through mass screening and in routine clinical practice. Acta Ophthalmologica Scandinavica. 2002;80(6):627-631. [pmid: 12485284].
29 Klein BE, Klein R, Sponsel WE, Franke T, Cantor LB, Martone J, et al. Prevalence of glaucoma. The Beaver Dam Eye Study. Ophthalmology. 1992;99(10):1499-1504. [pmid: 1454314].
30 Collaborative Normal-Tension Glaucoma Study Group. Comparison of glaucomatous progression between untreated patients with normal-tension glaucoma and patients with therapeutically reduced intraocular pressures. American Journal of Ophthalmology. 1998;126(4):487-497. [pmid: 9780093].
31 Collaborative Normal-Tension Glaucoma Study Group. The effectiveness of intraocular pressure reduction in the treatment of normal-tension glaucoma. American Journal of Ophthalmology. 1998;126(4):498-505. [pmid: 9780094].
32 Leske MC, Heijl A, Hussein M, Bengtsson B, Hyman L, Komaroff E, et al. Factors for glaucoma progression and the effect of treatment: the Early Manifest Glaucoma Trial. Archives of Ophthalmology. 2003;121(1):48-56. [pmid: 12523884].
33 The Glaucoma Laser Trial (GLT). 2. Results of argon laser trabeculoplasty versus topical medicines. The Glaucoma Laser Trial Research Group. Ophthalmology. 1990;97(11):1403-1413. [pmid: 2255512].
34 The Glaucoma Laser Trial (GLT). 5. Subgroup differences at enrollment. Glaucoma Laser Trial Research Group. Ophthalmic Surg. 1993;24(4):232-240. [pmid: 8321504].
35 The Glaucoma Laser Trial (GLT) and glaucoma laser trial follow-up study: 7. Results. Glaucoma Laser Trial Research Group. American Journal of Ophthalmology 1995;120(6):718–731.
36 AGIS (Advanced Glaucoma Intervention Study) Investigators. The Advanced Glaucoma Intervention Study (AGIS): 1. Study design and methods and baseline characteristics of study patients. Controlled Clinical Trials. 1994;15(4):299-325. [pmid: 7956270].
37 AGIS (Advanced Glaucoma Intervention Study) Investigators. The Advanced Glaucoma Intervention Study (AGIS): 12. Baseline risk factors for sustained loss of visual field and visual acuity in patients with advanced glaucoma. American Journal of Ophthalmology. 2002;134(4):499-512. [pmid: 12383806].
38 AGIS (Advanced Glaucoma Intervention Study) Investigators. The Advanced Glaucoma Intervention Study: 8. Risk of cataract formation after trabeculectomy. Archives of Ophthalmology. 2001;119(12):1771-1779. [pmid: 11735786].
39 AGIS (Advanced Glaucoma Intervention Study) Investigators. The Advanced Glaucoma Intervention Study (AGIS): 9. Comparison of glaucoma outcomes in black and white patients within treatment groups. American Journal of Ophthalmology. 2001;132(3):311-320. [pmid: 11530042].
40 National Research Council. Committee on Disability Determination for Individuals with Visual Impairments. Visual Impairments: Determining Eligibility for Social Security Benefits. Lennie P, Van Hemel SB, editors. National Academies Press, 2002.
41 Gutierrez P, Wilson MR, Johnson C, Gordon M, Cioffi GA, Ritch R, et al. Influence of glaucomatous visual field loss on health-related quality of life. Archives of Ophthalmology. 1997;115(6):777-784. [pmid: 9194730].
42 Cassard SD, Patrick DL, Damiano AM, Legro MW, Tielsch JM, Diener-West M, et al. Reproducibility and responsiveness of the VF-14. An index of functional impairment in patients with cataracts. Archives of Ophthalmology. 1995;113(12):1508-1513. [pmid: 7487617].
43 Mangione CM, Lee PP, Pitts J, Gutierrez P, Berry S, Hays RD. Psychometric properties of the National Eye Institute Visual Function Questionnaire (NEI-VFQ). NEI-VFQ Field Test Investigators. Archives of Ophthalmology. 1998;116(11):1496-1504. [pmid: 9823352].
44 Parrish RK, Gedde SJ, Scott IU, Feuer WJ, Schiffman JC, Mangione CM, et al. Visual function and quality of life among patients with glaucoma. Archives of Ophthalmology. 1997;115(11):1447-1455. [pmid: 9366678].
45 McHorney CA, Ware JE Jr, Lu JF, Sherbourne CD. The MOS 36-item Short-Form Health Survey (SF-36): III. Tests of data quality, scaling assumptions, and reliability across diverse patient groups. Medical Care. 1994;32(1):40-66. [pmid: 8277801].
46 Ramrattan RS, Wolfs RC, Panda-Jonas S, Jonas JB, Bakker D, Pols HA, et al. Prevalence and causes of visual field loss in the elderly and associations with impairment in daily functioning: the Rotterdam Study.[erratum appears in Archives of Ophthalmology 2002 Apr;120(4):525]. Archives of Ophthalmology. 2001;119(12):1788-1794. [pmid: 11735788].
47 Heijl A, Leske MC, Bengtsson B, Bengtsson B, Hussein M. Early Manifest Glaucoma Trial Group. Measuring visual field progression in the Early Manifest Glaucoma Trial. Acta Ophthalmologica Scandinavica. 2003;81(3):286-293. [pmid: 12780410].
48 Lee BL, Wilson MR. Health-related quality of life in patients with cataract and glaucoma. Journal of Glaucoma. 2000;9(1):87-94. [pmid: 10708237].
49 Katz JS, Congdon NM, Friedman DS. Methodological variations in estimating apparent progressive visual field loss in clinical trials of glaucoma treatment. Archives of Ophthalmology. September. 1999;117(9):1137-1142. [pmid: 10496384].
50 European Glaucoma Prevention Study Group. The European glaucoma prevention study design and baseline description of the participants. Ophthalmology. 2002;109(9):1612-1621. [pmid: 12208707].
51 Jampel HD. We should treat fewer patients with elevated intraocular pressure now that we know the results of the Ocular Hypertension Treatment Study. Archives of Ophthalmology. 2004;122(3):378-379. [pmid: 15006855].
52 West SK, Rubin GS, Broman AT, Munoz B, Bandeen-Roche K, Turano K. How does visual impairment affect performance on tasks of everyday life? The SEE Project. Salisbury Eye Evaluation. Archives of Ophthalmology. 2002;120(6):774-780. [pmid: 12049583].
53 Gordon MO, Kass MA. The Ocular Hypertension Treatment Study: design and baseline description of the participants. Archives of Ophthalmology. 1999;117(5):573-583. [pmid: 10326953].
54 Leske MC, Heijl A, Hyman L, Bengtsson B. Early Manifest Glaucoma Trial: design and baseline data. Ophthalmology. 1999;106(11):2144-2153. [pmid: 10571351].
55 Musch DC, Lichter PR, Guire KE, Standardi CL. The Collaborative Initial Glaucoma Treatment Study: study design, methods, and baseline characteristics of enrolled patients. Ophthalmology. 1999;106(4):653-662. [pmid: 10201583].
56 Janz NK, Wren PA, Lichter PR, Musch DC, Gillespie BW, Guire KE, et al. The Collaborative Initial Glaucoma Treatment Study: interim quality of life findings after initial medical or surgical treatment of glaucoma. Ophthalmology. 2001;108(11):1954-1965. [pmid: 11713062].