# Discussion

In this review, we examined one randomized clinical trial of treatment of ocular hypertension^21^ and four randomized trials of treatment for POAG (including one follow-up study).^12^–^14,^ ^31,^ ^33,^ ^35,^ ^37,^ ^39^ Table 1 provides a summary of the evidence from each trial. The OHTS study,^21^ the EMGT study,^12^ the CNTGS study,^31^ and the GLT study^35^ were rated to be of “good” or “fair” quality based on accepted USPSTF criteria.^16^ The quality of the AGIS trial^37^ was rated “poor.” No adjustments were made for 44 of 789 eyes that were excluded from the analysis because of incomplete data. Thus, analyses of the trial results were not reported based on intent-to-treat. The GLT follow-up study^35^ was also rated to be of “poor” quality for the same reason, although the primary trial^14,^ ^33^ was rated “fair.”

The OHTS and EMGT studies provide good evidence that treatment for ocular hypertension and early POAG is beneficial.^12,^ ^21^ Because only a small percentage of people with ocular hypertension ever progress to POAG, screening and treatment for ocular hypertension is probably not warranted, particularly given the poor sensitivity and specificity of IOP measurements in detecting increased IOP.^7^ If ocular hypertension is incidentally found as part of a routine eye examination, treatment may be warranted if IOP is substantially increased.^51^ Also, we do not know whether the results of the EMGT trial, which was conducted among whites in Scandinavia, will generalize to the U.S. population, particularly with the increased incidence of POAG among African Americans.

The CNTGS provides fair evidence that lower IOP does delay progression of normal-tension glaucoma.^31^ In this study, progression events were not counted until IOP reduction targets were reached. For the control group, counting of progression events was delayed based on time intervals matching time to achieve targeted IOP reduction in the treated group. When study data were analyzed based on intent-to-treat,^31^ participants were considered to be randomized when a progression occurred or when risk factors were present initially, such as a threat to fixation. This resulted in inclusion of more progression endpoints in both groups than were excluded in the first analysis.^30^ In the intent-to-treat analysis,^31^ similar numbers of progression events and similar rates of progression were seen in treated vs. untreated participants. A secondary analysis, which shows that treatment appeared effective if participants were censored at the time of cataract formation, is suspect because it implicitly assumes that those with cataracts would not experience further visual field progression after censoring. Because treatment, particularly surgical trabeculectomy, is a significant risk factor for cataract formation, this creates a strong bias favoring treatment.

Three trials and one follow-up study compared different interventions for treatment of POAG. The CIGTS study compared surgical trabeculectomy with a stepped-medication regime (plus ALT if necessary) to achieve target IOP reductions in participants with newly diagnosed glaucoma and IOP ≥ 20 mm Hg.^13^ After 4 years of follow-up, no difference in outcomes was seen between groups based on a study-defined visual field score. Also, there was no significant change from baseline visual field scores in either treatment group. This finding is difficult to interpret because progression was observed in all other studies of treatment of POAG.^12,^ ^14,^ ^35,^ ^37^ The CIGTS investigators conclude that both medical and surgical treatment result in similar visual field outcomes. In the CIGTS study, 38.1% of participants were black. In an analysis controlling for treatment effect of age and gender, non-white race remained a significant predictor of progression (OR 1.50; 95% CI, 1.08–2.07).

The GLT study compared initial treatment with ALT to a stepwise regimen of topical and systemic ocular hypotensive medications.^14,^ ^33^ In the first 3.5 years median follow-up, approximately the same number of eyes showed persistent visual field deterioration (12% ALT; 14% medication, NS). In a follow-up study,^35^ 203 of the original participants were followed for a median duration of 7 years. Compared with baseline measures at study inception, ALT-treated eyes showed significantly less visual field loss than medication-treated eyes (p = 0.005), although the difference was small (-0.1 dB for medical vs. ALT treatment). The investigators conclude that ALT is at least as efficacious as medication for initial treatment of POAG.

The AGIS study compared outcomes for two sequences of surgical trabeculectomy (T) or ALT (A): ATT or TAT.^36^ At 10 years, there was no significant difference in risk of visual field progression between the two treatment sequences (p = 0.11).^37^ Surgical trabeculectomy as the initial procedure resulted in greater loss of visual acuity than initial treatment with ALT (p = 0.007). This finding was associated with an increased risk of cataracts following surgical trabeculectomy, whether as the first or second intervention in a sequence (p = 0.004). In comparing outcomes for white vs. black participants,^39^ white participants appeared to fare much better with the TAT sequence, and black participants fared slightly better with the ATT sequence.

The benefit of treatment for POAG appears to be primarily related to the level of IOP elevation. Although the CNTGS study provided evidence that IOP does play some pathogenic role in the disease,^30^ treatment to lower IOP does not lead to improved outcomes.^31^ In the EMGT trial, in which approximately half of participants had normal-tension glaucoma,^12^ most of the benefit for treatment appeared to be in participants with elevated IOP.^32^ In the CIGTS study,^13^ all participants had increased IOP. Although no untreated control group was available, no progression in visual field loss was observed with either medication or surgery. As noted above, this finding is difficult to interpret since progression was observed to some extent in all other trials.

Taken together, these trials provide fair to good evidence that treatment is effective in slowing the progression of visual field loss for persons with POAG. The greatest benefit of treatment appears to be in those with increased POAG. Treatment appears to benefit blacks as well as whites, although POAG may be a more aggressive disease in blacks. Since the distribution of IOP is similar in blacks and whites,^5^ other pathogenic factors must account for this difference.

The benefits of treatment must also be weighed against its potential harms. The chief harm of treatment is an excess risk of cataract formation, which is particularly associated with surgical treatment.^12^ Ophthalmologists we have spoken with indicate that cataract formation is not considered to be a serious complication, since lens extraction is a simple procedure with low morbidity. In all trials, however, surgical treatment was associated with decreased visual acuity that persisted over time. Visual acuity is an independent risk factor for decreased vision-related quality of life,^41^ and contributes significantly to impaired performance of everyday tasks of living.^52^ In the several trials comparing surgical, laser, and medical treatment,^13,^ ^14,^ ^35,^ ^37^ there was little difference between outcomes. This finding suggests that the least invasive approach that will lower IOP would be best, in order to minimize harms.

There is good evidence that visual field loss is related in a linear fashion to vision-specific QOL.^41,^ ^44^ As discussed above, there is fair to good evidence that treatment of POAG is effective in slowing the progression of visual field loss for persons with POAG. The lack of a criteria standard for classifying progression of glaucoma makes it difficult to relate the intermediate outcome of visual field loss to the functional outcomes of visual impairment. Even among studies, there is poor agreement between different methods of defining progression.^49^ Reportedly, there are studies that are ongoing or nearing publication that may establish a clearer link between specific amounts of visual field loss and vision-related QOL.

Presently there are no good tests that would support a population-screening program for glaucoma. There are ongoing trials in larger populations of both the Henson Visual Field Analyzer and FDT perimetry for glaucoma screening. Based on the Malmö screening study,^28^ it is conceivable that a significant proportion of persons with undiagnosed glaucoma are already being seen by ophthalmologists and optometrists for other reasons. If so, then including both automated visual field testing and dilated eye examination as part of the comprehensive adult eye examination^27^ could result in a significant increase in the number of undiagnosed cases of glaucoma that are detected early in their course.

The yield of population screening for glaucoma is related to the number of individuals found who have a treatable form of glaucoma. The EMGT investigators compared screened patients (32,918 attended from a population of 42,947 invited) to self-selected patients seen in the eye clinic of the regional hospital in the prior year.^28^ They found 354 patients with a previous glaucoma diagnosis in the clinic, of whom 92% met the EMGT criteria. In the population screening, 401 of 402 (99%) met the EMGT criteria. Among self-selected patients, only 14% had NTG. Among screened patients, 53% had NTG. Since treatment of NTG is apparently not effective in reducing the rate of progression, based on the intent-to-treat analysis of the CNTGS data,^31^ fewer than half of patients identified from screening would benefit from screening.

With the exception of the EMGT study, in which participants were obtained from population screening, all other trials were conducted with participants who were self-selected through referral to an ophthalmologist. Self-selected patients probably represent a different spectrum of disease than presents in the general population. In one study comparing self-selected individuals with glaucoma to individuals identified through population screening, the self-selected group had significantly higher mean IOP measurements, two-thirds fewer cases of NTG, and significantly greater visual field deficits at the time of diagnosis.^28^ It is not clear how such differences would affect generalization of these trial results to a population setting.

In order to promote better understanding of treatment for increased intraocular pressure and primary open-angle glaucoma, further research is needed. We suggest that such research should include development of standardized and objective measures for glaucoma progression and visual field loss; validation of such measures in relation to vision-specific and general health status measures across the entire spectrum of disease; double-blind, placebo-controlled trials for early disease interventions; and population-based trials of screening instruments in multiple geographic locales to determine whether accurate, reliable, and practical approaches to screening exist.