# Results

Our combined database searches located 246 abstracts and titles for review. Seven citations were identified from these searches along with 12 from the 2002 review and 7 from outside sources, with 4 duplicates eliminated. After reviewing the 22 full-text articles, 13 were included in the update, 8 were excluded (Appendix C), and one article described an ongoing study. Appendix D summarizes the MEDLINE search and retrieval results.

Appendix D. MEDLINE® Search and Retrieval Results

## Key Question 1. Is there new evidence that screening for open-angle glaucoma reduces severe visual impairment?

We found no studies assessing the screening and treatment of open-angle glaucoma in a population setting.

## Key Question 3. Is there new evidence that feasible screening tests are accurate and reliable in detecting increased intraocular pressure or open-angle glaucoma?

The diagnosis of POAG is based on the finding of characteristic degenerative changes in the optic disc, along with a progressive loss of visual field sensitivity and development of scotomas, or blind spots in the field of vision. In addition, the angle between the iris and the cornea, which together form the anterior chamber of the eye, must be “open” or normal. Secondary causes of glaucoma, such as steroid use or trauma, must also be excluded. The finding of increased IOP, once considered a part of the definition of POAG, is no longer required, since IOP may be persistently normal in 25–50% of those with glaucomatous optic nerve damage.^4^ In such patients, a definitive diagnosis of glaucoma may require demonstration of progressive visual loss over time, since non-progressive glaucomatous damage may also be seen on a single exam when secondary causative factors, such as prior steroid use, are no longer present.^17^

Progressive changes in the optic nerve head are characteristic of POAG, and may include increased cupping of the optic nerve head, asymmetry in the amount of cupping between eyes, and optic disc hemorrhages. Either direct ophthalmoscopy of the dilated eye or slit lamp examination may be used to examine the optic nerve head. Direct ophthalmoscopy has a reported sensitivity of 59% and a specificity of 73% in detecting and classifying optic disc changes associated with glaucoma.^18^ Even among experts, however, there is wide variability in both interobserver agreement and intraobserver reliability in detecting glaucomatous optic disc progression.^19^ Consequently, using current methods, optic nerve assessment is neither a practical nor reliable tool for population screening.

Although increased intraocular pressure is a principal risk factor for glaucoma, the effectiveness of IOP measurement as a population-screening tool for either ocular hypertension or POAG is limited. In one population-based survey, increased IOP above 21 mmHg, the usual cutoff point for the diagnosis of ocular hypertension, was found to have a sensitivity of 47.1% and a specificity of 92.4% for diagnosing glaucoma. There was no value of IOP that provided a reasonable balance of sensitivity and specificity, and tonometry did not perform better in high-risk groups defined by age, race, gender, or family history.^7^ Because IOP fluctuates over time and diurnally, 50% of those with increased IOP may have normal readings on a single measurement. The performance of tonometry, as a test for ocular hypertension or POAG, also varies based on the proportion of those having either condition in the test population (i.e., spectrum bias), as well as other biases that affect evaluations of its performance.^20^ Also, while the risk of glaucoma rises with increasing IOP, most individuals with ocular hypertension will never develop glaucoma.^3,^ ^5,^ ^21^

Characteristic patterns of visual field loss also assist in making a definitive glaucoma diagnosis.^11^ Perimetry is a technique for assessing visual field loss by mapping a patient's response to visual stimuli presented in various locations within the visual field. Perimetry may be performed by manual or automated methods. The sensitivity and specificity of perimetry varies based on the method used, the cutoff point for defining visual field defects, as well the test used as the gold standard.^22^ At the present time, perimetry has a limited role in population-screening programs because of the expense of equipment, the amount of time necessary for testing (up to 10–20 minutes per eye), and the relative lack of portability of most instruments.

One instrument, the Henson Visual Field Analyzer, is already in use for population screening by the organization Prevent Blindness America. In a study of this instrument, no abnormal results were found in a test of 82 normal subjects.^23^ In 83 cases of glaucoma and suspected glaucoma referred to specialty clinics, the test identified 38 of 39 who had moderate to severe visual field loss and 49 of 58 patients who had any abnormality on visual field testing using Humphrey perimetry as a gold standard. While this indicates that this instrument may have both high sensitivity and specificity in diagnosing glaucoma, assessment of its true sensitivity and specificity would require further evaluation in an unselected population setting.

A newly developed technique for assessing visual field loss, frequency-doubling technology (FDT) perimetry, holds promise as a screening instrument because of its portability, ease of administration, and short time required for testing. Using a rapid screening mode, the test may be performed in less than 90 seconds.^24^ In a study of 137 patients referred to a glaucoma specialist, the test had a reported sensitivity of 95% and a specificity of 93% for detecting moderate to severe glaucoma.^25^ As for the Henson Visual Field Analyzer, population studies of FDT perimetry are needed to determine its true performance as a screening tool. Studies examining the use of the Henson Visual Field Analyzer and FDT perimetry in larger populations are reportedly under way or nearing publication.

The benefit of any screening program may be limited by the low prevalence of glaucoma in the general population.^24,^ ^26^ For example, if the prevalence of glaucoma is 1.5% in an unselected population of whites, and the screening test used is IOP measurement, with sensitivity of 47% and specificity of 92% for diagnosing glaucoma with an IOP measurement over 21 mmHg, then the predictive value of a positive test will be 8.2%.^7^ For every case of glaucoma identified, however, 11 individuals with a false-positive test would be referred for further diagnostic evaluation and possible unnecessary treatment.

Rather than relying on a single screening test, combined use of two or more screening tests might be considered. For example, Prevent Blindness America combines visual field testing (Henson Visual Field Analyzer) with IOP measurement in its screening algorithm.^23^ A combined testing strategy, however, may not improve the accuracy of testing, particularly if the sensitivity and specificity of each test are similar.^24^ An individual with disease would have additional opportunities to be identified by a positive test, so sensitivity would be expected to increase. At the same time, each healthy individual would have an increased chance of a false-positive test, so specificity would decrease.

The yield of a population-screening program would be based on the number of new cases of glaucoma detected incidental to usual care. As part of the comprehensive adult medical eye evaluation,^27^ the American Academy of Ophthalmology recommends visual fields by confrontation; intraocular pressure measurement; and examination of the fundus: vitreous, retina, vasculature, and optic nerve. The guideline also states that a dilated pupil examination is necessary for optimal evaluation of structures posterior to the iris, including the optic nerve.

We were not able to identify studies that directly assessed the sensitivity and specificity of the adult medical eye examination for the diagnosis of glaucoma. A study from Sweden compared persons with glaucoma identified through population screening with self-selected patients seen in clinical practice.^28^ From 1992 to 1997, population screening was carried out in residents aged 57 to 79 in Malmö, Sweden. Self-selected patients with glaucoma were identified by a retrospective review of records for patients seen in the prior year at the Eye Department of the Malmö University Hospital. Among 4,117 patients with a visit in the prior year, 354 had a diagnosis of glaucoma. Screening was carried out in 32,818 persons in the population, and 402 persons with previously undiagnosed cases of glaucoma were identified. Among the screened population, 250 of 402 (62%) had previously been seen by an ophthalmologist, and 67 of 402 (17%) had been seen in the 2 years prior to screening. This study suggests that a more extensive eye examination, including automated visual field screening and a dilated pupil examination in all patients, may increase the likelihood that glaucoma is detected as part of usual ophthalmologic care.

## Key Question 4. Is there new evidence that treating increased intraocular pressure reduces the incidence of primary open-angle glaucoma?

Increased intraocular pressure is the principal risk factor for development of POAG.^26^ The Ocular Hypertension Treatment Study (OHTS)^21^ was a randomized clinical trial comparing ocular hypotensive medications with no treatment in 1,636 individuals with increased intraocular pressure without evidence of visual field deficits or optic disc changes indicative of POAG. Participants were recruited from patients referred to 22 clinical centers. Based on USPSTF rating criteria,^16^ the quality of the OHTS study was rated “good” (Table 1).

Table 1 Evidence Table

Study | Population | Interventions | Main Outcomes/Results | Adverse Effects | Quality
OHTS | N = 1,636 | Treatment: stepped regimen of topical ocular hypotension medications | Primary endpoint: development of POAG: VF loss or optic disc changes | (treatment vs. control) | GOOD
Kass et al, 2002^21^ | Age: 40–80 yr (mean 55.4); male 34%; white 70% | Control: observation | Results: 60 months (treatment vs. control) Cumulative probability of POAG development (4.4% vs. 9.5%) (NNT 19.6) | Ocular symptoms: dryness, tearing, itching (57% vs. 47%) (NNH 10, p < 0.001)
Gordon and Kass, 1999 | Inclusion criteria: increased IOP (24–32 mm Hg) without POAG | Follow-up: 72 mo for African Americans; 78 mo for others | Hazard ratio of POAG development 0.40 (95% CI, 0.27–0.59, p < 0.0001). | Symptoms affecting skin, hair, and nails: (23% vs. 18%) (NNH 20, p < 0.001)
| Setting: U.S., 22 specialty centers | | In African Americans, POAG development (6.9% vs. 12.7%) (NNT 17.6) | Serious psychiatric events: (1.5% vs. 0.5%) (NNH 100, p = 0.05)
| | | Hazard ratio for POAG development 0.54 (95% CI, 0.28–1.03) | Serious genitourinary symptoms: (5.5% vs. 3.4%) (NNH 48, p = 0.04)
EMGT | N=255 | Treatment: ALT plus topical betaxolol eye drops | Primary endpoint: progression of glaucoma: VF loss and/or optic disc changes | (treatment vs. control) | GOOD
Heijl et al, 2002^12^ | Age: 50–80 yr (mean 68.1); male 34%; almost 100% white | Control: no initial treatment | Results: 48 mo (treatment vs. control) progression (30% vs. 49%, p = 0.004) (NNT 5.3, 95% CI, 4.3–14.3) | Ocular symptoms: NS
Leske et al, 1999 | Inclusion criteria: newly detected glaucoma based on VF defects, no prior treatment | Follow-up: (treatment vs. control) 66 vs. 69 mo | Partial follow-up to 102 mo, median time to progression (66 vs. 48 mo) | Mortality: death (12% vs. 5.7%, p = 0.08); cause-specific mortality judged to be typical for the age and gender composition of each group
| Setting: Sweden, population-based screening and specialty referrals | Range 51–102 mo | | Cataracts: cataract formation was more likely in treated vs. control patients (p = 0.002); risk of cataracts related to treatment increased over time (p = 0.02); cataract surgery (6 vs. 2, NS)
CNTGS | N = 145 participants | One eye of each participant randomized to | Primary endpoint: progression of VF loss, change in optic head, hemorrhage in optic disc. | (treatment vs. control) | FAIR
CNTG Study Group, 1998^30,^ ^31^ | Age: mean age 66 yr (treated group 66.3, control group 65.5); male 34%; white 83% | Treatment: medical or surgical management to achieve IOP reduction of 30% from baseline | Results: Endpoints were observed in 33% of the treatment group and 39% in the control group (p = 0.21). | Cataracts: (35% vs. 14%) (p = 0.0011). | Outcomes assessors not blinded to treatment group assignment, duration of follow-up not recorded, treatment group had higher IOP at baseline.
| Inclusion criteria: glaucoma based on VF or optic disc changes, and no recorded IOP > 24 mm Hg | Control: no treatment | Mean survival time was not significantly different: 4.9 yr (treatment) vs. 4.2 yrs (control). | Within the treated group, 48% of surgically treated, 25% treated with medications and laser trabeculoplasty only
| Setting: U.S., 24 specialty centers | Randomization occurred when high-risk VF defects or new optic disc hemorrhages were found.
CIGTS | N = 607 | Treatment 1: surgical trabeculectomy | Primary endpoint: VF progression based on a measure derived from VF testing | (surgery vs. medication) | FAIR
Lichter et al, 2001^13^ | Age: 25–75 yr (surgery group mean 58.1, medicine group mean 56.9); male 55%; white 56% | Treatment 2: stepped regimen of topical ocular hypotension medications | Secondary endpoints: VA, change in IOP, occurrence of cataracts, QOL | Cataracts: (17.3% vs. 6.2%) (NNH 90, p = 0.0001). | Outcomes assessors not blinded to treatment group assignment
Musch et al, 1999 | Inclusion criteria: newly diagnosed glaucoma | Follow-up: Interim results based on complete follow-up to 48 mo | Results: At 60 mo VF scores remained virtually unchanged from baseline in both groups. | Surgical complications: (30 days post-operative): bleeding in the anterior chamber (7.1%); conjunctival buttonhole defects (1.0%); shallow or flat anterior chamber (14.2%); failed filtering bleb (11.9%); ptosis (11.9%); serous choroidal detachment (11.3%); anterior chamber bleeding or hyphema (10.5%).
Janz et al, 2001 | Setting: U.S., 14 specialty centers | | VA was significantly worse for surgery group until 48 mo, when average VA became equal across groups.
| | | QOL based on multiple eye-related and general health measures. Surgery group had more problems with VA (p = 0.024). QOL between treatment groups NS. Worry about blindness decreased from 50% at baseline to 25% over time.
GLT | N = 542 eyes, 271 patients | One eye of each patient received stepped regimen of topical medication, and the fellow eye was treated with ALT with medications added if needed. | Primary endpoint: number of medications required to control IOP | Ocular and systemic symptoms were reported for all patients. No comparative data since each patient received both treatments. | FAIR
GLT Research Group: GLT 2, 1990 | Age: ≥ 35 yr (mean 60 yr); male 44%; white 45% | Follow-up: 24 mo | Secondary endpoints: VF loss, VA | | Outcomes assessors not blinded to treatment group assignment; method for VF measurement changed after start of trial
| Inclusion criteria: newly diagnosed glaucoma with IOP > 22 mm Hg | | Results: At 24 months more eyes in the medication group required two or more medications to control IOP (p < 0.001).
| Setting: U.S., 8 specialty centers | | No significant differences between groups regarding VA or VF.
GLT Research Group: GLT 6, 1995^14^ | Follow-up study | Follow-up: 3.5 yr | Results: 12% of ALT-treated eyes vs. 14% of medication-treated eyes had persistent VF loss
GLTFS | Follow-up study | Follow-up: 6–9 yr | Results: ALT-treated eyes showed improved VF status (mean change per test location +0.5 to 1.1 dB) through 7 years of follow-up, and deterioration at 8 (-0.3 dB) and 9 (-1.5 dB) years. Medically treated eyes showed improvement in the first 3 years (+0.1 to 0.6 dB), and no change or deterioration thereafter (0.0 to -2.3 dB). The overall difference in VF status was significant but small (-0.01 db for medical vs. ALT treatment, p = 0.005). There were no observed differences in VA between eyes based on initial treatment (p = 0.276). | | POOR
GLT Research Group: GLT 7, 1995^35^ | N = 203 of 271 patients from GLT | | | | Analysis not based on intent-to-treat: no adjustment for missing data for 68 patients from original study lost to follow-up; outcomes assessors not masked to treatment assignment group
AGIS | N = 789 eyes of 591 participants | 2 sequences of surgical trabeculectomy (T) or ALT (A). | Primary outcomes: Sustained decrease of visual field (SVDF) and sustained decrease of visual acuity (SDVA). | Cataracts developed in more that half of eyes in the study, and more cataracts developed in eyes initially treated with surgery (57.4%) than with ALT (48.9%). The relative risk of cataract following surgical trabeculectomy, whether as the first or second intervention in a sequence, was 1.78 (p = 0.004). | POOR
AGIS 1, 1994^36^ | Age: 35–80 yr (median 67 yr); male 46%; white 42% | Treatment 1: TAT | Results: | | Analysis not based on intent-to-treat: 44 eyes excluded from analysis due to incomplete measurements; outcomes assessors not masked to treatment assignment group
AGIS 12, 2002^37^ | Inclusion criteria: advanced POAG based on IOP measurements, VF changes, optic disc changes | Treatment 2: ATT | At 10 years, the SDVF endpoint was reached in 30% of eyes. There was no significant difference in risk of progression between the two treatment sequences (p = 0.11).
| Setting: U.S., 11 specialty centers | Next treatment in sequence used if progression occurs | SDVA endpoints occurred in 34.2% of eyes treated with TAT vs. 25.6% of ATT eyes (p = 0.007).
| | Follow-up: median 10.8 yr | Baseline VF scores were significantly lower for black participants than for white participants (p < 0.001);baseline IOP scores and VA scores were similar. Relative risk of reaching an SDVF or SDVA endpoint over 9 years of follow-up was similar for blacks and whites, and no significant advantage was seen for either treatment regimen.

AGIS, Advanced Glaucoma Intervention Study; ALT, argon laser trabeculoplasty; CI, confidence interval; CIGTS, Collaborative Initial Glaucoma Treatment Study; CNTGS, Collaborative Normal-Tension Glaucoma Study; EMGT, Early Manifest Glaucoma Trial; GLT, Glaucoma Laser Treatment; GLTFS, Glaucoma Laser Treatment follow-up study; IOP, intraocular pressure; NNH, number needed to harm; NNT, number needed to treat; NS, not significant; OHTS, Ocular Hypertension Treatment Study; POAG, primary open-angle glaucoma; QOL, quality of life; VA, visual acuity; VF, visual field

The primary endpoint was development of visual field deficits and/or optic disc changes, indicating progression to POAG. At 60 months follow-up, progression to POAG occurred in 4.4% of those treated with medications vs. 9.5% of untreated participants. The “number needed to treat” (NNT) to prevent one case of progression from ocular hypertension to POAG was 19.6. Over the duration of the study, the hazard ratio for progression of ocular hypertension to POAG in all treated vs. untreated participants was 0.40 (95% CI, 0.27–0.59).

To study the benefit of treatment for ocular hypertension in blacks, recruitment for the OHTS study was stratified to include 408 (25%) blacks. At 72 months, the median duration of follow-up for black participants, progression to POAG occurred in 6.9% of those receiving medications vs. 12.7% of those not treated (NNT, 17.9). The hazard ratio for progression of ocular hypertension to POAG in treated vs. untreated black participants was 0.54 (95% CI, 0.28–1.03) compared with a hazard ratio of 0.34 (95% CI, 0.21–0.56) for other participants. This difference was not statistically significant.

## Key Question 5. Is there new evidence that treating increased intraocular pressure reduces severe visual impairments?

We found no studies that assessed the treatment of ocular hypertension using delay of progression to severe visual impairment as an endpoint.

## Key Question 6. Is there new evidence that treating open-angle glaucoma with drugs, laser, and/or surgery reduces severe visual impairment?

We identified two studies that examined treatment of newly diagnosed glaucoma with medication, argon laser treatment, or surgery compared with untreated control subjects.

The Early Manifest Glaucoma Trial (EMGT)^12^ was a randomized clinical trial comparing treatment with no treatment in 255 individuals with early POAG. Participants, virtually all of whom were white, were identified through population screening of 44,243 individuals, aged 50 and older, in Malmö and Helsingborg, Sweden. Based on USPSTF rating criteria,^16^ the quality of the EMGT study was rated “good” (Table 1).

Overall, 531 (1.2%) of those screened were found to have glaucoma. This was similar to the prevalence of glaucoma among whites in other population-screening studies.^2,^ ^3,^ ^6,^ ^29^ The diagnosis of early glaucoma was based on: the presence of repeatable, but not severe, visual field defects; no previous diagnosis or treatment for POAG; and mean IOP of 30 mm Hg or less. Of the 531 individuals with glaucoma, 255 (48%) met the entry criteria for early glaucoma and agreed to participate in the study. Among these, 132 participants (53%) had normal-tension glaucoma based on repeated IOP measurements less than 21 mm Hg.

One hundred and twenty-nine participants were randomized to treatment with argon laser trabeculoplasty (ALT) and topical beta-blocker eye drops. The remaining 126 control participants received no treatment. The primary trial endpoint was progression of POAG based on new visual field loss, optic disc deterioration, or both. At 48 months, the minimum planned follow-up, 30% of treated subjects reached a progression endpoint vs. 49% of control subjects (NNT, 5.3; 95% CI, 4.35–14.29). In survival analyses, median time to progression was 66 months in the treatment group and 48 months in control patients. The risk of progression decreased by 10% for each 1 mm Hg reduction in IOP. In multivariate analyses, no treatment effects were observed other than those related to IOP reduction.

In the Collaborative Normal-Tension Glaucoma Study (CNTGS),^30^ 145 eyes of 145 individuals with manifestations of POAG, but without recorded IOP elevation (>24 mm Hg) on repeated testing, were randomized to receive treatment with medications or surgery to lower IOP by 30%, or to receive no treatment. Participants were recruited from patients referred to 24 ophthalmic practices, mainly at university-affiliated medical centers. Participants were followed for approximately 5 years. Based on USPSTF rating criteria,^16^ the quality of the CNTGS study was rated “fair” (Table 1).

Randomization occurred at the time that high-risk visual field defects (threat to central fixation), progressive visual field defects, or new optic disc hemorrhages were found. The primary intent of this study was to examine the role of IOP in the pathogenesis of NTG by comparing outcomes of untreated patients with outcomes of treated patients in whom targeted IOP reductions were achieved. The endpoint for progression was defined as worsening of an existing visual field defect, the appearance of new visual field defects, or a new threat to central visual fixation. Baseline measurements for assessing progression were obtained at the time that target IOP reductions were achieved in the group assigned to medication or surgery. To adjust for potential biasing effects of time delays in the untreated control eyes, baseline measurements were obtained after a delay matched to the corresponding delays in the treated group. Five patients who withdrew from the trial protocol before IOP stabilization were excluded from analyses.

A total of 35 progression endpoints were observed. Seven of 61 eyes (12%) in the treated group reached progression endpoints compared with 28 of 79 (35%) in the untreated group. The mean survival time to progression in the treated eyes was 2,688 ± 123 days, compared with 1,695 ± 143 days in untreated eyes (p < 0.0001). These findings indicate that IOP is part of the pathogenic process in normal-tension glaucoma, and that lowering IOP may be beneficial in its treatment.

In a companion paper,^31^ analysis of the same patients was performed based on intent-to-treat. In this analysis, progression endpoints were assessed from the time of randomization for all eyes. The five eyes excluded from the treatment group in the first study were included in the intent-to-treat analysis. Progression was defined on the basis of the same endpoint used in the first paper. A total of 53 progression endpoints were observed. Twenty-two of 66 eyes (33%) in the treated group reached a progression endpoint, compared with 31 of 79 eyes (39%) in the untreated group. The mean survival time to progression in the treated eyes was 1,796 ± 151 days, compared with 1,525 ± 152 days in untreated eyes (p = 0.21). Apparently, the additional 18 endpoints included in this analysis occurred prior to the time when baseline measurements were obtained for the first analysis.

In the CNTGS study, 23 of 66 treated eyes (35%) developed loss of visual acuity due to cataracts, compared with 11 of 79 eyes in the control group (14%) (p = 0.0011). The highest incidence of cataracts (16 of 33) occurred in the surgically treated eyes. The rate of cataract formation in untreated eyes was lower than surgically treated eyes (p = 0.0001), but was not significantly different from medically treated eyes (p = 0.18).

In a secondary analysis of the intent-to-treat data, observations were censored at the time cataracts were diagnosed. This resulted in an apparent improvement in survival time before glaucoma progression for treated eyes compared with control eyes (p = 0.008). This assumes, however, that eyes censored from observation after cataracts developed would not develop progression endpoints in the future. Since cataract formation does not protect against glaucomatous progression, and because treatment increases the risk of cataract formation, this creates a strong bias favoring treatment.

The first CNTGS ^30^ paper indicates that IOP does play a pathogenic role in normal-tension glaucoma. However, the results of the second paper^31^ do not indicate whether treating IOP would effectively reduce glaucoma progression in patients with NTG. In the EMGT study, secondary analyses show that increased IOP is a significant risk factor for progression (For IOP ≥ 21 mm Hg, HR 1.70, 95% CI, 1.18–2.43 vs. IOP < 21 mm Hg).^32^ This indicates that treatment directed at lowering IOP is definitely beneficial for eyes with increased IOP, but of uncertain benefit in eyes with normal IOP.

Three other studies compared different treatment interventions, without untreated controls, in individuals with POAG. In the Collaborative Initial Glaucoma Treatment Study (CIGTS), 607 individuals with newly diagnosed glaucoma were recruited from self-selected patients at 14 clinical centers. Forty-four percent of participants were non-white. Participants were randomized to treatment with surgical trabeculectomy (n = 300), an incisional surgical technique to lower IOP, or to a stepwise medication regimen (n = 307).^13^ Target values for IOP reduction were calculated using baseline IOP measurements combined with results of visual field testing, so that the target of IOP was lower if greater visual field loss was evident at baseline. ALT was also performed in the medication group, if needed, to achieve targeted IOP reductions. The primary outcome was a study-defined visual field (VF) score based on perimetry testing. Based on USPSTF rating criteria,^16^ the quality of the CIGTS study was rated “fair” (Table 1).

After complete follow-up through 4 years, there was no difference in VF scores between treatment groups. Because the baseline VF score in the medically treated group was lower, though not significantly, the investigators conducted secondary analyses to adjust for this difference. These analyses showed a slight advantage for surgical treatment although the difference was marginally significant. In the CIGTS study, 38.1% of participants were black. In an analysis controlling for treatment effect of age and gender, non-white race was a significant predictor of progression (OR 1.50; 95% CI, 1.08–2.07), defined as a decrease in visual field score ≥ 3 units.

Visual acuity (VA) measures in surgically treated patients were 2.3 letters lower than for medically treated patients (p = 0.0001), which clinically accounts for a difference of ½ line on a VA chart. Surgically treated patients had a significantly higher rate of cataract extractions (52/300; 17.3%) than medically treated patients (19/307; 6.2%) (p = 0.0001). In secondary analyses adjusting for cataract extractions, VA outcomes in surgically treated patients remained significantly lower (p = 0.0001). Race was marginally significant as a predictor of decreased visual acuity over time.

In the CIGTS study, VF scores remained essentially unchanged from baseline for both treatment groups over the course of the study. In the EMGT study, both treated and untreated groups experience progression over time, although the rate of progression was significantly lower in the treated group.^12^ This difference between studies may be explained in part by differences in baseline IOP measurements between studies. In the EMGT study, 52% of participants had baseline IOP < 21 mm Hg (treatment group mean IOP 20.6 ± 4.1; control group mean IOP 20.9 ± 4.1). In the CIGTS study, all participants had baseline IOP ≥ 20 mm Hg (medicine group mean IOP 27.6 ± 5.5 mm Hg; surgery group mean IOP 27.4 ± 5.7 mm Hg). In the EMGT study, IOP was a strong risk factor for progression, and the risk of progression decreased by 10% for each 1 mm Hg lowering of IOP.^12,^ ^32^

The hypothesis that treatment is more beneficial for those with high-tension glaucoma (IOP ≥ 21 mm Hg), compared with normal-tension glaucoma, is also supported by the CNTGS findings.^31^ Based on intent-to-treat analysis, there was no significant difference in outcomes between treated eyes and untreated eyes with normal-tension glaucoma.

The CIGTS investigators conclude that both medical and surgical treatment result in similar VF outcomes. They caution, however, that 4 to 5 years of follow-up in a chronic disease is not adequate to draw treatment conclusions, and that the CIGTS findings do not support a change in current treatment approaches to POAG.^13^

The Glaucoma Laser Treatment (GLT)^33^ study compared initial treatment with ALT to a stepwise regimen of topical and systemic ocular hypotensive medications. Patients were recruited at 8 tertiary care clinical centers. Thirty-two percent of participants had received glaucoma treatment prior to study entry. Forty-four percent of participants were black, and all participants had elevated IOP at baseline (IOP ≥ 22 mm Hg; mean IOP 27.3 mm Hg).^34^ Based on USPSTF rating criteria,^16^ the quality of the GLT study was rated “fair” (Table 1).

Among 271 participants with POAG, one eye was randomized to laser treatment, and its companion eye to treatment with medications. Medications were added for eyes in either group if targeted IOP reductions were not achieved, or if visual field or optic disc deterioration was seen. The primary endpoint of the GLT study, the number of medications required to control IOP for laser treated vs. medically treated eyes, was reported in 1990.^33^

After 24 months, targeted IOP reduction was achieved in 44% of eyes treated with ALT alone, and 33% of eyes treated with topical beta-blocker eye drops (p < 0.001). Targeted IOP reduction was achieved in 89% of eyes treated with ALT first, with or without subsequent addition of medications, and 66% of eyes treated with medication only (p < 0.001). After 24 months of follow-up, 56% of eyes treated with ALT required supplemental medication, although significantly more eyes in the medication group required simultaneous administration of two or more medications to control IOP (p < 0.001). There were no observed differences between treatment groups in either visual acuity or visual field changes over 24 months.

In a subsequent report after median follow-up of 3.5 years, 23% of eyes initially treated with ALT showed visual field deterioration on at least one occasion, compared with 31% of eyes treated with medication (p = 0.02). Approximately the same proportion of eyes (12% ALT; 14% medication) had persistent visual field deterioration on repeated exams.^23^ In a later report,^35^ 203 of the original participants were followed for a median duration of 7 years. Sixty-eight participants were not enrolled in the follow-up study because of death (18), serious illness (7), refusal (14), or because they could not be located or had moved out of the study area (29). Because there was no adjustment for missing participants, the analysis was not based on intent-to-treat. Based on USPSTF rating criteria,^16^ the quality of the GLT follow-up study was rated “poor” (Table 1).

Compared with baseline measures at study inception, ALT-treated eyes showed improved visual field status (mean change per test location +0.5 to1.1 dB) through 7 years of follow-up, and deterioration at 8 (-0.3 dB) and 9 (-1.5 dB) years. Medically treated eyes showed improvement in the first 3 years (+0.1 to 0.6 dB), and no change or deterioration thereafter (0.0 to -2.3 dB). The overall difference in visual field status was significant but small (-0.1 dB for medical vs. ALT treatment, p = 0.005). There were no observed differences in visual acuity between eyes based on initial treatment (p = 0.276). The investigators conclude that ALT is at least as efficacious as medication for initial treatment of POAG.

The Advanced Glaucoma Intervention Study (AGIS)^36^ compared outcomes for two sequences of surgical trabeculectomy (T) or ALT (A): ATT or TAT. Patients were recruited from patients referred to 11 clinical centers. All participants had advanced POAG based on a combination of IOP measurements, visual field deterioration, and optic disc changes. All participants were receiving maximal medical therapy for glaucoma at the time of enrollment. Fifty-six percent of participants were black.

In this study, 789 eyes of 591 participants were randomized to either ATT or TAT sequences. The primary outcomes were changes in visual function as measured by changes in visual field or visual acuity measures. In a report on two measures,^37^ sustained decrease of visual field (SDVF) and sustained decrease of visual acuity (SDVA), the AGIS investigators analyzed outcomes for 745 of 789 enrolled eyes (94.4%) after median follow-up of 10.8 years. Forty-four eyes were excluded from the analysis because of loss-to-follow-up (1 eye), mistakenly receiving the same intervention that the fellow eye was randomized to (2 eyes in the same participant), or less than 3 follow-up visits at which visual outcomes were measured (41 eyes). Because there was no adjustment for missing participants, the analysis was not based on intent-to-treat. Based on USPSTF rating criteria,^16^ the quality of the AGIS study was rated “poor” (Table 1).

At 10 years, an SDVF endpoint was reached in 30.3% of eyes. There were no significant differences in risk of progression between the two treatment sequences (p = 0.11). SDVA endpoints occurred in 34.2% of eyes treated with surgical trabeculectomy initially vs. 25.6% of eyes treated with ALT initially (p = 0.007). Cataracts developed in more that half of eyes in the study, and more cataracts developed in eyes initially treated with surgery (57.4%) than with ALT (48.9%).^38^ The relative risk of cataract following surgical trabeculectomy, whether as the first or second intervention in a sequence, was 1.78 (p = 0.004).

Baseline VF scores were significantly lower for black participants than for white participants (p < 0.001), although baseline IOP scores and VA scores were similar. Comparing black with white participants, the relative risk of reaching an SDVF or SDVA endpoint over 9 years of follow-up was 1.51 (95% CI, 0.92–2.46) and 1.39 (95% CI, 0.90–2.12), respectively. Fewer SDVF endpoints were reached in white participants undergoing ATT than TAT (p = 0.002). Fewer SDVA endpoints were reached in black participants undergoing TAT than ATT (p < 0.001). Overall, white participants appeared to fare better with TAT and black participants with ATT.^39^

### The Relation of Visual Field Loss to Functional Impairment

For this update, we adopted the key questions proposed by RTI-UNC in its topic review. In these questions, the critical questions regarding benefits of treatment specify “severe visual impairment” as the outcome. Interpretation of the benefits of treatment based on this outcome is difficult. Although POAG is one of the most common causes of blindness in the U.S.,^1^ only a small proportion of affected individuals will eventually become blind.^11^ In a National Academies of Science report on visual impairment and disability,^40^ the panel concluded that there was no scientific basis for choosing any threshold of vision loss for disability determination.

A more salient concern may be the relation between visual field loss of any degree and its impact on vision-specific functioning, general health status, and quality of life (QOL). In a study of vision-specific QOL in patients with glaucoma,^41^ there was a linear relationship between increased visual field loss and decreased vision-specific QOL, as measured by previously validated National Eye Institute visual function questionnaires.^42,^ ^43^ The study also found that visual field loss and visual acuity were independent predictors of vision-specific QOL.

A second study examining the impact of binocular visual field impairment, using the same questionnaires,^44^ found significant correlations between binocular visual field loss and impairment of peripheral vision activities (r = 0.60), distance activities (r = 0.56), and vision-specific dependency (r = 0.56). When adjusted for visual acuity, the magnitudes of these correlations were weaker (r, -0.32 to -0.44) but remained significant. Both studies found, at most, a weak relationship between visual field loss and MOS-36 (Medical Outcomes Study 36-Item Short Form) general health status.^45^

A population-based survey from Rotterdam of the association of visual field loss and impairment of daily activities^46^ found that persons with bilateral visual field loss or severe unilateral visual field loss were significantly more likely to be moderately or severely disabled; unable to enjoy reading or television; require a walking aid; have a history of hip or wrist fracture; or experience more than 4 falls within 2 years after initial evaluation. Visual acuity in persons with visual field loss was significantly lower compared with those without visual field loss; however, the associations above remained significant after adjusting for low visual acuity.

For ethical reasons, the treatment studies presented here used sensitive indicators of progression to minimize the impact of visual field loss in untreated or less intensively treated participants. The Early Manifest Glaucoma Trial investigators described the relationship between their visual field progression endpoint and conventional method of measuring visual field loss.^47^ For example, the mean deviation (MD) at baseline for affected eyes was -5.0 dB in the treatment group and -4.4 dB in the control group (p = NS).^12^ In eyes reaching progression, the mean change in MD from baseline was -1.93 (95% CI, -2.31 to -1.54). By comparison, the MD for a functionally blind eye would be around -25 dB or worse.^12^ In regression analyses, the changes in MD from baseline were found to be independent of baseline IOP, baseline MD, or time to progression.

Presently, there is no clear way to quantitatively relate specific degrees of visual field loss to impairment of vision-specific QOL, and studies examining these associations have not established a relationship between changes in vision-specific QOL and specific treatment approaches.^48^ The EMGT investigators assessed vision-specific QOL using the National Eye Institute Visual Function Questionnaire, ^43^ but these data have not been reported at this time.

There is also no standard definition for visual field progression. A study comparing measures of progression from 3 different studies (EMGT, CIGTS, and AGIS) demonstrated significant variations in classification of progression depending on which method was used.^49^ When applied to longitudinal observations on 67 eyes of 56 participants in a natural history study of glaucoma, a total of 22 of 67 eyes (32.8%) were classified as having visual field progression based on any of the three methods. For individual methods, AGIS classified 7 of 67 persons (10.4%) as having visual field progression, compared with 14 of 67 persons (21%) with EMGT criteria and 13 of 67 (19.4%) with CIGTS criteria. The EMGT and CIGTS methods, used in studies of newly diagnosed glaucoma, appear to be more sensitive than the AGIS method, used in a study of advanced glaucoma. In the 22 persons classified as having visual field progression overall, the methods agreed on classification of progression in only 5 of 22 persons (23%).

## Key Question 7. Is there new evidence that screening results in adverse effects? Is screening acceptable to patients?

We found no new studies addressing the harms or acceptability of screening for ocular hypertension or POAG. Known short-term adverse effects of screening include eye irritation and dysgeusia associated with topical anesthetics; corneal abrasions and infections with instruments that touch the eye; and apprehensiveness about the exam.

## Key Question 8. Is there new evidence that treatment of increased intraocular pressure and/or open-angle glaucoma results in adverse effects?

Most of the included trials provide information on the possible harms associated with treatment based on comparisons between groups. Ocular symptoms, such as dryness, tearing, and itching, were frequently reported. In the OHTS study, for example, ocular symptoms occurred in 57% of treated patients and 47% of control subjects (p < 0.001).^21^ Other symptoms, such as darkening of the eyelids or eyelash growth, were reported in 23% of treated patients vs. 18% of control subjects (p < 0.001).

The CIGTS trial reported intraoperative and postoperative complication for surgical trabeculectomy in 525 participants. Intraoperative complications included bleeding in the anterior chamber (7.1%) and conjunctival buttonhole defects (1.0%). Complications within 30 days postoperatively included shallow or flat anterior chamber (14.2%); failed or encapsulated filtering bleb (11.9%); ptosis (11.9%); serous choroidal detachment (11.3%); and anterior chamber bleeding, or hyphema (10.5%).^13^ The long-term implication of these complications was not reported.

Serious systemic adverse effects of treatment were also reported. In the EMGT study, more participants died in the in the group treated with topical medications and ALT (15 of 22) than in the untreated control group (7 of 22, p = 0.08).^12^ Most of these deaths occurred among males in the first 2 years of the study. The patterns of cause-specific mortality, primarily cardiovascular events and malignancy, were similar to those expected in a population of the same age and gender.

In the OHTS study, there were no observed differences between the treated and untreated participants in total hospitalizations, worsening of preexisting conditions, or mortality.^21^ Serious psychiatric adverse effects were reported in 5.5% (44 of 800) of the treated group vs. 3.4% (27 of 802) of the control group (p = 0.05). Serious genitourinary adverse effects occurred in 1.5% (12of 800) of the treated group vs. 0.5% (4of 802) of the control group (p = 0.04). There was no evident biological connection between these complications and the medications used. There was also no significant difference in the likelihood of these complications after adjustment for multiple comparisons.

There is a known association between surgical treatment for open-angle glaucoma and an increased risk of cataract formation.^12^ In the CIGTS study, with no adjustment for variable follow-up, more cataracts requiring extraction occurred in the surgically treated group (17.3%) than in the medically treated group (6.2%).^13^ In survival analyses, adjusted rates of cataract extraction were 11.6% in the surgery group vs. 2.7% in the medical group. Over time, the cataract extraction rate in the surgery group remained significantly higher than in the medication group (p = 0.0001).

Two other studies compared the risks of cataract formation in medically treated vs. untreated eyes. In the EMGT study,^12^ cataract development was more likely in group treated with ALT plus betaxolol than in untreated control subjects (p = 0.002), and the risk of cataracts related to treatment increased over time (p = 0.02). Cataract extraction was performed in 6 (4.8%) treatment group participants and 2 (1.8%) control participants, which was a nonsignificant difference. In the OHTS study of individuals with ocular hypertension without glaucoma, there were slightly more cataract extractions in medically treated participants (52 of 806, 6.4%) than in untreated control subjects (35 of 813, 4.3%). This difference was not significant (p = 0.06).^21^

## Excluded Studies

Studies excluded from this evidence synthesis are shown in Appendix C. Reasons these studies were not considered include a study design other than randomized controlled trial was used; there were large attrition rates; or the analysis was not based on intent-to-treat.

## Ongoing Trials

The European Glaucoma Prevention Study is a randomized, double-blinded, controlled trial comparing a topical medication (dorzolamide) to placebo in preventing or delaying progression to POAG.^50^ Between January 1997 and May 1999, 1,077 participants were enrolled and randomized. Follow-up will continue for 5 years or until a specified number of participants have developed visual field or optic disc changes characteristic of POAG.