# Methods

The Oregon Evidence-based Practice Center performed an evidence synthesis with particular focus on the critical examination of glaucoma treatment trials published since the 1996 USPSTF recommendation was issued. In addition, we looked for new information regarding harms of either treatment or screening.

As a prelude to this review, the Research Triangle Institute-University of North Carolina Evidence-based Practice Center (RTI-UNC EPC) conducted a preliminary literature review to determine if a sufficient amount of new evidence existed to warrant a more complete evidence synthesis. The RTI-UNC EPC conducted a MEDLINE search for new studies from 1994 through 2002. In addition, 11 expert reviewers were contacted for comments. We used the RTI-UNC EPC search strategy, keywords, and terms to conduct additional searches from January 2001 through January 2004 (Appendix A). Titles and abstracts from the RTI-UNC EPC review and our updated search were downloaded into an electronic bibliographic database. Titles and abstracts were reviewed for possible inclusion by two investigators [CF, EW] based on specific inclusion/exclusion criteria. (Appendix B) We obtained copies of all studies meeting the inclusion criteria. In addition, we obtained studies cited by the RTI-UNC EPC expert reviewers or identified through our expert contacts, from the 1996 USPSTF recommendation,^15^ and from review of study bibliographies. We rated trials meeting inclusion criteria for quality based on accepted USPSTF criteria.^16^ Study quality was rated as good if adequate randomization methods were used; treatment and control groups were comparable at baseline; loss to follow-up was accounted for and comparable groups were maintained throughout the study; outcomes were determined by objective criteria or by assessors masked to group randomization assignment; appropriate statistical methods were used; and analysis was based on intent-to-treat. To guide our review, we focused on a set of key questions addressing the benefits and harms of treatment and screening (Figure 1).

Figure 1. Primary Care Screening for Increased Intraocular Pressure and Open-AngleGlaucoma Analytic Framework and Key Questions