# References

1 National Center for Injury Prevention and Control. WISQARS (Web-based Injury Statistics Query and Reporting System). Web Page. Available at: http://www.cdc.gov/ncipc/wisqars/.
2 National Institute of Mental Health. Suicide facts. accessed June 30, 2002. Web Page. Available at: http://www.nimh.nih.gov/research/suifact.html.
3 Office of the Surgeon General. The Surgeon General's Call to Action to Prevent Suicide. Washington, DC: Department of Health and Human Services, US Public Health Service; 1999.
4 US Department of Health and Human Services, Public Health Service. National Strategy for Suicide Prevention: Goals and Objectives for Action. Rockville, MD: US Department of Health and Human Services, Public Health Service; 2001.
5 Brown G K, Beck A T, Steer R A, Grisham J R. Risk factors for suicide in psychiatric outpatients: a 20-year prospective study. J Consult Clin Psychol. 2000;68:371-377. [pmid: 10883553].
6 Hirschfeld R M, Russell J M. Assessment and treatment of suicidal patients. N Engl J Med. 1997;337:910-915. [pmid: 9302306].
7 Pignone M P, Gaynes B N, Rushton J L, et al. Screening for depression in adults: a summary of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2002;136:765-776. [pmid: 12020146].
8 American Psychiatric Association. Practice guideline for the treatment of patients with major depressive disorder. Am J Psychiatr. 2000;157:7.
9 Zametkin A J, Alter M R, Yemini T. Suicide in teenagers: assessment, management, and prevention. JAMA. 2001;286:3120-3125. [pmid: 11754678].
10 Murphy S L. Deaths: final data for 1998. Natl Vital Stat Rep. 2000;48:1-105. [pmid: 10934859].
11 Hawton K, Townsend E, Arensman E, et al. Psychosocial and pharmacological treatments for deliberate self harm (Cochrane Review). The Cochrane Library. 2001;Oxford: Update Software.
12 Hawton K, Harriss L, Simkin S, Bale E, Bond A. Deliberate Self-Harm in Oxford 1999. Annual Report From Centre for Suicide Research. Oxford: University of Oxford; 2000.
13 van der Sande R, van Rooijen L, Buskens E, et al. Intensive in-patient and community intervention versus routine care after attempted suicide. A randomised controlled intervention study. Br J Psychiatry. 1997;171:35-41. [pmid: 9328492].
14 Gilbody S, House A, Owens D. The early repetition of deliberate self harm. J R Coll Physicians Lond. 1997;31:171-172. [pmid: 9131517].
15 Gunnell D, Frankel S. Prevention of suicide: aspirations and evidence. BMJ. 1994;308:1227-1233. [pmid: 8080520]. [pmcid: 2540097].
16 Crockett A W. Patterns of consultation and parasuicide. Br Med J (Clin Res Ed). 1987;295:476-478. [pmid: 3117178].
17 Sansone R A, Wiederman M W, Sansone L A, Monteith D. Patterns of self-harm behavior among women with borderline personality symptomatology: psychiatric versus primary care samples. Gen Hosp Psychiatry. 2000;22:174-178. [pmid: 10880710].
18 Gorman D, Masterton G. General practice consultation patterns before and after intentional overdose: a matched control study. Br J Gen Pract. 1990;40:102-105. [pmid: 2112010]. [pmcid: 1371074].
19 Greenhill L L, Waslick B. Management of suicidal behavior in children and adolescents. Psychiatr Clin North Am. 1997;20:641-666. [pmid: 9323318].
20 Grunbaum J A, Kann L, Kinchen S A, et al. Youth risk behavior surveillance--United States, 2001. MMWR Morb Mortal Wkly Rep. 2002;51:1-62.
21 Druss B, Pincus H. Suicidal ideation and suicide attempts in general medical illnesses. Arch Intern Med. 2000;160:1522-1526. [pmid: 10826468].
22 Cooper-Patrick L, Crum R M, Ford D E. Identifying suicidal ideation in general medical patients. JAMA. 1994;272:1757-1762. [pmid: 7966924].
23 Olfson M, Weissman M M, Leon A C, Sheehan D V, Farber L. Suicidal ideation in primary care. J Gen Intern Med. 1996;11:447-453. [pmid: 8872781].
24 Zimmerman M, Lish J D, Lush D T, Farber N J, Plescia G, Kuzma M A. Suicidal ideation among urban medical outpatients. J Gen Intern Med. 1995;10:573-576. [pmid: 8576774].
25 Mann J J. A current perspective of suicide and attempted suicide. Ann Intern Med. 2002;136:302-311. [pmid: 11848728].
26 Schmidtke A, Bille-Brahe U, DeLeo D, et al. Attempted suicide in Europe: rates, trends and sociodemographic characteristics of suicide attempters during the period 1989-1992. Results of the WHO/EURO Multicentre Study on Parasuicide. Acta Psychiatr Scand. 1996;93:327-338. [pmid: 8792901].
27 Safer D J. Adolescent/adult differences in suicidal behavior and outcome. Ann Clin Psychiatr. 1997;9:61-66.
28 Callahan C M, Hendrie H C, Nienaber N A, Tierney W M. Suicidal ideation among older primary care patients. J Am Geriatr Soc. 1996;44:1205-1209. [pmid: 8855999].
29 Bartels S J, Coakley E, Oxman T E, et al. Suicidal and death ideation in older primary care patients with depression, anxiety, and at-risk alcohol use. Am J Geriatr Psychiatry. 2002;10:417-427. [pmid: 12095901].
30 Skoog I, Aevarsson O, Beskow J, et al. Suicidal feelings in a population sample of nondemented 85-year-olds. Am J Psychiatry. 1996;153:1015-1020. [pmid: 8678169].
31 Anderson RN. Deaths: Leading Causes for 1999. Hyattsville, Md: National Center for Health Statistics; 2001.
32 Borowsky I W, Resnick M D, Ireland M, Blum R W. Suicide attempts among American Indian and Alaska Native youth: risk and protective factors. Arch Pediatr Adolesc Med. 1999;153:573-580. [pmid: 10357296].
33 Kachur SP, Potter LB, James SP, Powell KE . Suicide in the United States, 1980-1992. Atlanta, GA: Centers for Disease Control and Prevention, National Center for Injury Prevention and Control; 1995. Violence Surveillance Summary Series; 1.
34 Blumenthal S J. Suicide: a guide to risk factors, assessment, and treatment of suicidal patients. Med Clin North Am. 1988;72:937-71. [pmid: 3287045].
35 Pirkis J, Burgess P. Suicide and recency of health care contacts. A systematic review. Br J Psychiatry. 1998;173:462-474. [pmid: 9926074].
36 Luoma J B, Martin C E, Pearson J L. Contact with mental health and primary care providers before suicide: a review of the evidence. Am J Psychiatry. 2002;159:909-916. [pmid: 12042175].
37 Robins E, Murphy G E, Wilkinson R H Jr, et al. Some clinical considerations in the prevention of suicide based on a study of 13 successful suicides. Am J Pub Health. 1959;49:888-899.
38 Frankenfield D L, Keyl P M, Gielen A, Wissow L S, Werthamer L, Baker S P. Adolescent patients--healthy or hurting? Missed opportunities to screen for suicide risk in the primary care setting. Arch Pediatr Adolesc Med. 2000;154:162-168. [pmid: 10665603].
39 US Preventive Services Task Force. Screening for suicide risk. Guide to Clinical Preventive Services. 2nd Edition. Baltimore: Williams and Wilkins; 1996:547–554.
40 Harris R P, Helfand M, Woolf S H, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20:21-35. [pmid: 11306229].
41 Townsend E, Hawton K, Altman D G, et al. The efficacy of problem-solving treatments after deliberate self-harm: meta-analysis of randomized controlled trials with respect to depression, hopelessness and improvement in problems. Psychol Med. 2001;31:979-988. [pmid: 11513383].
42 Cotgrove A, Zirinsky L, Black D, Weston D. Secondary prevention of attempted suicide in adolescence. Am J Adoles. 1995;18:569-577.
43 Harrington R, Kerfoot M, Dyer E, et al. Randomized trial of a home-based family intervention for children who have deliberately poisoned themselves. J Am Acad Child & Adolesc Psychiatry. 1998;37:512-518. [pmid: 9585653].
44 Wood A, Trainor G, Rothwell J, Moore A, Harrington R. Randomized trial of group therapy for repeated deliberate self-harm in adolescents. J Am Acad Child Adolesc Psychiatry. 2001;40:1246-1253. [pmid: 11699797].
45 Brown GK. Suicide assessment measures for intervention research with adults and older adults. Web Page. Available at: http://www.nimh.nih.gov/research/adultsuicide.pdf.
46 Goldston DB. Assessment of suicidal behaviors and risk among children and adolescents. 2000. Web Page. Available at: http://www.nimh.nih.gov/research/measures.
47 Horowitz L M, Wang P S, Koocher G P, et al. Detecting suicide risk in a pediatric emergency department: development of a brief screening tool. Pediatrics. 2001;107:1133-1137. [pmid: 11331698].
48 Broadhead W E, Leon A C, Weissman M M, et al. Development and validation of the SDDS-PC screen for multiple mental disorders in primary care. Arch Fam Med. 1995;4:211-219. [pmid: 7881602].
49 Spitzer R L, Williams J B, Gibbon M, First M B. The Structured Clinical Interview for DSM-III-R (SCID). I: History, rationale, and description. Arch Gen Psychiatry. 1992;49:624-629. [pmid: 1637252].
50 Sheehan D, Knapp E, Sheehan M, Baker R. Mini-International Neuropsychiatric Interview Clinician Rated, Version 4.0. Tampa, FL: University of South Florida College of Medicine; 1992.
51 Beck A T, Kovacs M, Weissman A. Assessment of suicidal intention: the Scale for Suicide Ideation. J Consult Clin Psychol. 1979;47:343-352. [pmid: 469082].
52 Reynolds W. Suicide Ideation Questionnaire. Odessa, Fl: Psychological Assessment Resources; 1987.
53 Pignone M, Gaynes B, et al. Screening for Depression: Systematic Evidence Review No 6. Rockville, Md: Agency for Healthcare Research and Quality, AHRQ Publication No. 02-S002; 2001.
54 Williams J W Jr, Pignone M, Ramirez G, Perez Stellato C. Identifying depression in primary care: a literature synthesis of case- finding instruments. Gen Hosp Psychiatry. 2002;24:225-237. [pmid: 12100833].
55 Bateman A, Fonagy P. Effectiveness of partial hospitalization in the treatment of borderline personality disorder: a randomized controlled trial. Am J Psychiatry. 1999;156:1563-1569. [pmid: 10518167].
56 Bateman A, Fonagy P. Treatment of borderline personality disorder with psychoanalytically oriented partial hospitalization: an 18-month follow-up. Am J Psychiatry. 2001;158:36-42. [pmid: 11136631].
57 Koons C R, Robins C J, Tweed J L, Lynch T R. Efficacy of dialectical behavior therapy in women veterans with borderline personality disorder. Behavior-Therapy. 2001;32:371-390.
58 Bennewith O, Stocks N, Gunnell D, Peters T J, Evans M O, Sharp D J. General practice based intervention to prevent repeat episodes of deliberate self harm: cluster randomised controlled trial. BMJ. 2002;324:1254. [pmid: 12028981]. [pmcid: 113279].
59 Bruce M L, Pearson J L. Designing an intervention to prevent suicide: PROSPECT (Prevention of Suicide in Primary Care Elderly: Collaborative Trial. Dialogues in Clin Neuroscience. 1999;1:100-112.
60 Brown G K, Bruce M L, Pearson J L. High-risk management guidelines for elderly suicidal patients in primary care settings. Int J Geriatr Psychiatry. 2001;16:593-601. [pmid: 11424168].
61 Guthrie E, Kapur N, Mackway-Jones K, et al. Randomised controlled trial of brief psychological intervention after deliberate self poisoning. BMJ. 2001;323:135-138. [pmid: 11463679]. [pmcid: 34723].
62 Rudd M D, Rajab M H, Orman D T, Joiner T, Stulman D A, Dixon W. Effectiveness of an outpatient intervention targeting suicidal young adults: preliminary results. J Consult Clin Psychol. 1996;64:179-190. [pmid: 8907098].
63 Montgomery D B, Roberts A, Green M, Bullock T, Baldwin D, Montgomery S A. Lack of efficacy of fluoxetine in recurrent brief depression and suicidal attempts. Eur Arch Psychiatry Clin Neurosci. 1994;244:211-215. [pmid: 7888419].
64 Evans MO, Morgan HG, Hayward A, Gunnell DJ . Crisis telephone consultation for deliberate self-harm patients: effects on repetition. Br J Psychiatry. 1999;175.
65 Motto J A, Bostrom A G. A randomized controlled trial of postcrisis suicide prevention. Psychiatr Serv. 2001;52:828-833. [pmid: 11376235].
66 Battaglia J, Wolff T K, Wagner-Johnson D S, Rush A J, Carmody T J, Basco M R. Structured diagnostic assessment and depot fluphenazine treatment of multiple suicide attempters in the emergency department. Int Clin Psychopharmacol. 1999;14:361-372. [pmid: 10565804].
67 Gibbons J S, Butler J, Urwin P, Gibbons J L. Evaluation of a social work service for self-poisoning patients. Br J Psychiatry. 1978;133:111-118. [pmid: 678733].
68 Hawton K, McKeown S, Day A, Martin P, O'Connor M, Yule J. Evaluation of out-patient counselling compared with general practitioner care following overdoses. Psychological Med. 1987;17:751-761.
69 Salkovskis P M, Atha C, Storer D. Cognitive-behavioural problem solving in the treatment of patients who repeatedly attempt suicide. A controlled trial. Br J Psychiatry. 1990;157:871-876. [pmid: 2289097].
70 McLeavey B, Daly R, Ludgate J, Murray C. Interpersonal problem-solving skills training in the treatment of self-poisoning patients. Suicide Life Threat Behav. 1994;24:382-394. [pmid: 7740595].
71 Evans K, Tyrer P, Catalan J, et al. Manual-assisted cognitive-behaviour therapy (MACT): A randomized controlled trial of a brief intervention with bibliotherapy in the treatment of recurrent deliberate self-harm. Psychological Med. 1999;29:19-25.
72 Chowdhury N, Hicks R C, Kreitman N. Evaluation of an after-care service for parasuicide (attempted suicide) patients. Soc Psychology. 1973;8:67-81.
73 Welu T C. A follow-up program for suicide attempters: evaluation of effectiveness. Suicide Life Threat Behav. 1977;7:17-20. [pmid: 206990].
74 Hawton K, Bancroft J, Catalan J, Kingston B, Stedeford A, Welch N. Domiciliary and out-patient treatment of self-poisoning patients by medical and non-medical staff. Psychol Med. 1981;11:169-177. [pmid: 7208740].
75 Allard R, Marshall M, Plante M C. Intensive follow-up does not decrease the risk of repeat suicide attempts. Suicide Life Threat Behav. 1992;22:303-314. [pmid: 1440744].
76 Van Heeringen C, Jannes S, Buylaert W, Henderick H, De Bacquer D, Van Remoortel J. The management of non-compliance with referral to out-patient after-care among attempted suicide patients: a controlled intervention study. Psychol Med. 1995;25:963-970. [pmid: 8588015].
77 Morgan H G, Jones E M, Owen J H. Secondary prevention of non-fatal deliberate self-harm. The green card study. Br J Psychiatry. 1993;163:111-112. [pmid: 8353677].
78 Linehan M M, Armstrong H E, Suarez A, Allmon D, Heard H L. Cognitive-behavioral treatment of chronically parasuicidal borderline patients. Arch Gen Psychiatry. 1991;48:1060-1064. [pmid: 1845222].
79 Liberman R P, Eckman T. Behavior therapy vs insight-oriented therapy for repeated suicide attempters. Arch Gen Psychiatry. 1981;38:1126-1130. [pmid: 7027988].
80 Torhorst A, Moller H J, Burk F, Kurz A, Wachtler C, Lauter H. The psychiatric management of parasuicide patients: a controlled clinical study comparing different strategies of outpatient treatment. Crisis. 1987;8:53-61. [pmid: 3595176].
81 Waterhouse J, Platt S. General hospital admission in the management of parasuicide. A randomised controlled trial. Br J Psychiatry. 1990;156:236-242. [pmid: 2180527].
82 Montgomery SA, Montgomery DB, Jayanthi-Rani S, . Maintenance therapy in repeat suicidal behaviour: a placebo controlled trial. Proceedings of the 10th International Congress for Suicide Prevention & Crisis Intervention. Ottawa, Canada: 1979:227–229.
83 Hirsch S R, Walsh C, Draper R. Parasuicide. A review of treatment interventions. J Affect Disord. 1982;4:299-311. [pmid: 6298293].
84 Montgomery S A, Roy D, Montgomery D B. The prevention of recurrent suicidal acts. Br J Clin Pharmacol. 1983;15(Suppl 2):183S-188S. [pmid: 6824553]. [pmcid: 1427879].
85 Verkes R J, Van der Mast R C, Hengeveld M W, Tuyl J P, Zwinderman A H, Van Kempen G M. Reduction by paroxetine of suicidal behavior in patients with repeated suicide attempts but not major depression. Am J Psychiatry. 1998;155:543-547. [pmid: 9546002].
86 Torhorst A, Moller HJ, Schmid-Bode KW. Comparing a 3-month and a 12-month-outpatient aftecare program for parasuicide repeaters. Current Issues of Suicidology. Berlin, Germany: Springer-Verlag; 1988:19–24.
87 Coryell W, Arndt S, Turvey C, et al. Lithium and suicidal behavior in major affective disorder: a case-control study. Acta Psychiatr Scand. 2001;104:193-197. [pmid: 11531655].
88 Raj M A J, Kumaraiah V, Bhide A V. Cognitive-behavioural intervention in deliberate self-harm. Acta Psychiatr Scand. 2001;104:340-345. [pmid: 11722314].
89 Pfeffer C R, Hurt S W, Kakuma T, Peskin J R, Siefker C A, Nagabhairava S. Suicidal children grow up: suicidal episodes and effects of treatment during follow-up. J Am Acad Child & Adolesc Psychiatry. 1994;33:225-230. [pmid: 8150794].
90 Rotheram-Borus M J, Piacentini J, Cantwell C, Belin T R, Song J. The 18-month impact of an emergency room intervention for adolescent female suicide attempters. J Consult Clin Psychol. 2000;68:1081-1093. [pmid: 11142542].
91 Montgomery S, Cronholm B, Asberg M, Montgomery D B. Differential effects on suicidal ideation of mianserin, maprotiline and amitriptyline. Br J Clin Pharmacol. 1978;5(Suppl 1):77S-80S. 77S-80S. [pmid: 341948]. [pmcid: 1429205].
92 Brent D A, Holder D, Kolko D, et al. A clinical psychotherapy trial for adolescent depression comparing cognitive, family, and supportive therapy. Arch Gen Psychiatry. 1997;54:877-885. [pmid: 9294380].
93 Patsiokas AT , Clum GA. Effects of psychotherapeutic strategies in the treatment of suicide attempters. 1985;22:281.
94 Beck AT, Schuyler D, Herman I. Development of suicidal intent scales. The Prediction of Suicide. Philadelphia, Pa: Charles Press; 1974:45–56.
95 Beck A T, Ward C H, Mendelson M, Mock J, Erbaugh J. An inventory for measuring depression. Arch Gen Psychiatry. 1961;41:561-571. [pmid: 13688369].
96 Hamilton Depressive Rating Scale (HAM-D): A rating scale for depression. J Neurol Neurosurg Psychiatry. 1960;23:56–61.
97 Tondo L, Hennen J, Baldessarini R J. Lower suicide risk with long-term lithium treatment in major affective illness: a meta-analysis. Acta Psychiatr Scand. 2001;104:163-172. [pmid: 11531653].
98 Ford C A, Bearman P S, Moody J. Foregone health care among adolescents. JAMA. 1999;282:2227-2234. [pmid: 10605974].
99 Rihmer Z, Rutz W, Pihlgren H. Depression and suicide on Gotland. An intensive study of all suicides before and after a depression-training programme for general practitioners. J Affect Disord. 1995;35:147-152. [pmid: 8749979].