# Discussion

Evidence for or against the value of screening for risk of suicide in primary care settings must be considered within a complex practice and epidemiologic context. Suicide is a rare outcome, even among high-risk groups; this fact alone creates methodological challenges. Randomized controlled trials (RCTs), the “gold standard” for showing efficacy in evidence reviews, ethically cannot include a true placebo arm; consequently, all interventions are being compared to treatment arms that in fact may (or may not) be effective. Finally, patterns of suicide behaviors are very complex. Although a prior suicide attempt is a strong risk factor for completed suicide, sociodemographic characteristics and behaviors clearly differ across groups who attempt suicide, practice repetitive deliberate self-harm behaviors (DSH), and successfully complete suicide. Focusing exclusively on completed suicide still reveals dramatic differences in rates and methods across the life span, between males and females, and between different race and ethnicity groups. Current research, in large part, does not address this complexity.

Within this context, we have reviewed literature published since 1966 with the goal of better defining the clinician's role in screening for suicide risk in primary care settings. Despite the public health import of suicide and the Surgeon General's call to action, evidence to guide the primary care clinician's assessment and management of suicide risk is extremely limited.

No studies exist that address the overarching question of whether screening for suicide risk in primary care patients improves outcome. Consequently, we must address this question by analyzing the studies addressing the intervening linkage questions.

Very little is known about use of screening instruments for suicide risk in primary care populations. In older adolescents and adults (ages 18 to 70 years), 1 prospective study identifies reasonable test characteristics for persons reporting that they were “feeling suicidal” compared to responses indicating the presence of a plan. This question was part of a more extensive case identification instrument designed for primary care. This study has not been replicated, nor has the specific question identified (“feeling suicidal”) been tested independently of the longer instrument. No screening instruments have been tested in primary care settings for children or young adolescents.

The evidence is fair and mixed that interventions to treat those at risk of suicide reduce suicide attempts or completions. Although some trends suggest incremental benefit from several interventions, no consistent statistically significant effects have emerged for interventions for which more than 1 study has been done. Of the interventions for which only 1 study had been done, promising interventions included dialectic behavioral therapy (DBT) for borderline personality disorder, ^78^ interpersonal psychotherapy (IPT) for DSH, ^61^ and group therapy specifically for children and adolescents with DSH. ^44^ These interventions, however, require further confirmation.

We should emphasize that our review did not include all of the available clinical trial literature involving suicide attempts or completions. Some literature has examined the effectiveness of medications such as lithium in the prevention of suicide among psychiatric patients with major mood disorders, as reflected in a recent meta-analysis by Tondo et al. ^97^ We did not include these studies in our review because they did not meet our inclusion criteria of a controlled trial with an adequate comparison group.

Several studies show improvement for intermediate outcomes, primarily for older adolescents and adults at high risk for DSH. Specifically, meta-analyses of RCTs using problem-solving therapy have shown benefit as indicated by improved mood, decreased hopelessness, and improvement in problems. ^41^ In addition, 1 RCT involving IPT ^61^ and 1 RCT involving DBT ^57^ have documented decreased suicidal ideation, and 1 cohort study of cognitive behavioral therapy (CBT) decreased suicidal ideation. ^88^ Similar decreases in suicidal ideation for adolescent groups have not been shown. ^43,^ ^44^ However, for adolescents 18 years of age and younger who have attempted suicide, 1 cohort study suggested that a brief emergency crisis intervention involving mother and daughter may decrease the number of patients with clinical relevant depressive symptoms at 18-month follow-up. ^90^

We found no information directly addressing the harms and costs of either screening or treatment. Such information is important to guide any conclusions about either screening or intervening for suicide risk, should evidence of beneficial treatments relevant to suicide prevention emerge.

## Priorities for a Research Agenda

Our review highlights several important issues involving research on the assessment and management of suicide risk. First, the challenge of studying interventions for a rare event is underscored by the fact that, even in a population with a relatively high risk of DSH (i.e., those who have already harmed themselves), documenting incremental benefit relative to standard care has been difficult. This difficulty is attributable at least in part to the fact that most studies are underpowered to detect significant differences, whereas studies that have larger sample sizes typically provide the least intense (and, arguably, likely less effective) interventions. ^58^ Future research must consider the feasibility of large, multi-site studies which could have sufficient power to identify the benefit of interventions for such a substantial health problem that is a relatively rare event.

Second, the generalizability of the available evidence to a primary care population with unidentified suicide risk is poor. The great majority of research has been conducted in psychiatric populations with an already identified risk for suicide, rather than among unidentified patients in primary care, who as a group are at lower risk. The existing literature includes only 1 screening study (of adults) conducted in a primary care setting. ^23^ Only 1 of the intervention studies involved patients recruited from primary care practices (although most were from mental health settings), ^57^ and all of the studies involved patients already identified as being at high risk for harming themselves (and, consequently, are likely to already be in treatment with a mental health professional). Only 1 study conducted the intervention in a primary care setting. ^58^ High priorities for future research are to examine the test characteristics of screens for suicide risk for all age groups in primary care settings and to recruit patients for intervention studies from primary care settings.

Third, the available studies focus on those with relatively moderate risk for suicide and, for ethical and clinical reasons, exclude patients at the highest risk. Most identified high-risk patients are likely admitted to a psychiatric unit for safety, which may (or may not) in itself be an effective intervention. Subsequent research should consider how to stratify at-risk primary care patients and target interventions to risk severity.

Fourth, the lack of evidence for incremental benefit from a particular intervention compared to standard care is not equivalent to saying that nothing works. There is no evidence that “no care” works. Standard care in many instances may be a successful intervention, indicating it is sufficient or that it is “good enough.” However, standard care is poorly described in the existing literature and likely is variable across studies, making the comparison to the experimental intervention difficult to evaluate. The exact components of standard care, which may be an effective intervention, are poorly understood. Subsequent research could address this shortcoming by attempting to more carefully monitor and define standard care.

Fifth, making meaningful conclusions specific to any particular age group is difficult. Very few studies have exclusively enrolled adolescents, and those that do typically enroll only young adolescents. Patients in mid to late adolescence (who are at highest risk) are often enrolled in adult studies, which have not been stratified by age; as a result, drawing conclusions specific to this age group is a challenge. In addition, despite the concern about increased risk of suicide in the elderly, there is a dearth of information to guide evidence-based assessment and management strategies in primary care. Results from the PROSPECT trial will begin to fill this void. ^59^ Subsequent research should involve populations with more clearly defined age groups and analyses stratified by age to allow more meaningful interpretation for specific high-risk age groups.

Sixth, dramatic differences in suicide behaviors among men and women, and among different racial and ethnic groups have drawn little attention. A better understanding of this variation may have direct implications for screening and treatment strategies, and they warrant further research.

Seventh, our review is relevant only to those individuals who access clinical care, which means that a large portion of the population may be ignored. Indeed, fully one-third of adolescents do not receive a physical examination by a clinician within the previous year; information on addressing this substantial group is even less clear. ^98^ Community-based research can presumably address this question.

Finally, we did not find studies meeting our inclusion criteria that addressed whether more adequate treatment of depressed patients or substance-abusing patients will decrease the risk of suicide. Of note, assessing suicidal ideation is the standard of care in the evaluation for depression, for which the U.S. Preventive Services Task Force now recommends routine screening. ^7^ Successful collection of pertinent clinical information during such screening requires the communication of sensitive information between the primary care clinician and patient and emphasizes the importance of the clinician-patient interaction. This routine screening will likely identify more patients with suicidal ideation, for which primary care clinicians will need evidence-based management strategies. Non-prospective studies have suggested that educating general practitioners on better identification and treatment of depression may be an effective method of suicide prevention. ^99^ Subsequent prospective primary care-based clinical trials are needed to develop this evidence base.