# Methods

## Analytic Framework and Key Questions

Using methods established by the US Preventive Services Task Force (USPSTF), ^40^ members of the RTI International - University of North Carolina Evidence-based Practice Center (RTI-UNC EPC) developed an analytic framework (Figure 1, see page 13) and 8 key questions (Table 1, see page 14) to guide our literature search. Our population of interest was primary care patients with unidentified suicide risk.

Table 1. Key Questions for Screening for Suicide Risk

Number | Question
1 | Does screening for suicide risk in primary care settings result in decreased attempts and/or decreased mortality?
2 | Can a screening test reliably detect suicide risk in primary care populations?
3 | Main outcome: For those identified as being at risk, does treatment result in decreased suicide attempts and/or decreased mortality from suicide?
4 | Intermediate outcome: For those identified as being at risk, does treatment result in decreased suicidal ideation, decreased depressive severity, decreased hopelessness, or improved level of functioning?
5 | What are the harms of screening?
6 | What are the costs of screening?
7 | What are the harms of treatment?
8 | What are the costs of treatment?

Figure 1. Screening for Suicide Risk: Analytic Framework

The first key question examined direct evidence connecting screening with decreased suicide attempts, fewer suicide completions, or both. Because we found no evidence for our overarching key question, we searched for indirect evidence for key questions 2 through 4. Key question 2 focused on the existence of validated screening tests for identifying suicide risk in a primary care setting. Key question 3 examined the efficacy of treatments to reduce suicide attempts or mortality (i.e., completed suicides) for those at risk of attempting suicide; key question 4 looked at intermediate outcomes, such as reducing suicidal ideation, reducing depressive severity, reducing hopelessness, and improving level of functioning. Key question 5 concerned the harms of screening; key question 6 examined the costs of screening. Similarly, key question 7 concerned the harms of treatment, and key question 8 examined the costs of treatment.

## Literature Search Strategy

We prospectively developed inclusion and exclusion criteria for selecting the evidence relevant to answering the key questions (Table 2, see page 15). We conducted 4 individual searches: (1) screening for suicide in primary care settings only, (2) randomized controlled trials (RCTs) of treatments for suicide risk in primary or specialty care settings, (3) cohort studies of treatment for suicide risk in primary care or specialty care settings, and (4) primary care reviews and meta-analyses for suicide in general. This search strategy reflected our conceptualization that screening must be performed in primary care but that, should suicide risk be identified, a primary care physician could refer for subsequent treatment. Furthermore, this strategy reflected the decision by the EPC staff and our Task Force liaisons, with concurrence by the entire USPSTF, that our systematic review of treatments initially consider only trials with prospective study designs. Should there not be a sufficient number of studies for review by this strategy, we would then consider a search of trials with retrospective study designs, such as case-control studies.

Table 2. Inclusion and Exclusion Criteria

Element | Inclusion | Exclusion
Databases | MEDLINE, PsycINFO | Other databases
Languages | English only | Other languages
Populations | Humans only | Animal studies
Study design | Randomized controlled trial, cross-sectional, cohort, systematic reviews and meta-analysis | Case-control, letters, editorials, and nonsystematic reviews
Study population | Screening: primary care | Screening: community settings and psychiatric settings
| Treatment: primary or specialty care | Treatment: community settings

All searches began with the terms “suicide” or “suicide, attempted”, and we subsequently used MEDLINE's “explode” feature, which takes advantage of the MeSH heading tree structure and picks up all terms that are more specific than the target term as well as the target term. We re-ran our searches after this initial pass and clarified that this search successfully identified all relevant studies involving “parasuicide,” “suicidal ideation,” “suicidal,” and “deliberate self-harm.” In addition, any studies conducted in community settings (such as a school) were excluded, as a separate review will address this milieu.

For screening studies, inclusion required comparison with a “gold standard.” For treatment studies, we included only those trials reporting suicide completions, suicide attempts, or suicidal ideation as main outcomes. We excluded clinical trials targeting patients with chronic psychotic illnesses because these subjects would already have been identified as being at risk of suicide. We also excluded RCTs that did not supply sufficient detail to allow us to directly compare outcomes between intervention and control groups. For cohort studies in particular, we excluded studies that did not have a similar clinical presentation for intervention and control groups (e.g., the general population was not an adequate control group) or did not have an independent control group (e.g., the same sample could not act as its own control at a different time).

To identify articles relevant to the screening and treatment of suicide risk, the EPC staff searched the MEDLINE database from 1966 to June 30, 2002 using search terms consistent with the inclusion criteria. We supplemented these sources by searching the Cochrane Collaboration Library; using the same search terms in PsycINFO; and hand searching the bibliographies of systematic reviews, relevant original articles, the second edition of the Guide to Clinical Preventive Services ^39^ The numbers of articles that met our criteria by search terms are documented in Table 3 (see page 16). The EPC staff with both Task Force liaison and full USPSTF agreement concluded that there were a sufficient number of prospective trials to preclude the need to review trials with retrospective study design.

Table 3. Literature Search Results: Screening

Step | Screening | Number of Articles in:
| | MEDLINE | PsycINFO
1 | Explode suicide/ or explode suicide, attempted | 24, 512 | 17,269
2 | Explode mass screening/ | 51,454 | 15,074
3 | 1 and 2 | 83 | 456
4 | Total unduplicated records from both databases | 250
| Met inclusion criteria | 1*
| Randomized Controlled Trials of Suicide Treatments | MEDLINE | PsycINFO
1 | Explode (suicide/ or explode suicide, attempted) and (explode randomized controlled trial/explode single-blind or double-blind method/explode random allocation) | 72 | 0
2 | Explode suicide/ or explode suicide, attempted | 26,541 | 17,269
3 | Limit 2 to randomized controlled trial | 123 | 0
4 | 1 or 3 | 215
5 | Randomized controlled trial | | 727
6 | 1 and 2 and 5 | | 7
7 | Limiting to human and English language, total unduplicated records from both databases | 222
| Met inclusion criteria | 33
| Cohort Studies of Treatment | MEDLINE | PsycINFO
1 | Explode suicide/ or explode suicide, attempted | 26,780 | 17,269
2 | Limit 1 to (human and English language) | 19,492
3 | Explode therapeutics/ or treatment.mp | 2,561,983
4 | 2 and 3 | 2,249
5 | Explode cohort studies | 438,625
6 | 4 and 5 | 522 | 109
7 | Total unduplicated records from both databases | 507
| Met inclusion criteria | 4
| Primary Care Reviews and Meta-Analyses | MEDLINE | PsycINFO
1 | Primary care reviews or meta-analyses | 54 | 47
2 | Total unduplicated records from both databases | 54
| Met inclusion criteria | 2

* 1 additional article abstracted; see text

We found 1 well-conducted, recent systematic review by Hawton et al. concerning treatment of deliberate self-harm, which was relevant to key question 3 (reducing suicide attempts or completions). ^11^ We found another recent, well-done systematic review relevant to intermediate outcomes (key question 4). ^41^ We checked studies from our searches against the studies in these reviews, and we examined in detail only those studies that had not been included in the systematic reviews. In our data synthesis step, we included the findings of the systematic reviews along with the additional studies that we reviewed in detail. Only 3 RCTs exclusively involved patients 17 years of age or younger. ^42–44^

## Literature Reviewed

All of the titles and abstracts were reviewed independently by 2 of the authors. If either reviewer determined that the study met the inclusion criteria based on the abstract, the full paper was retrieved for further evaluation. The studies were subject to an additional review by 2 of the authors to finalize inclusion, with disagreements resolved by a systematic resolution of discrepancies; we considered the study's relevance to the systematic search inclusion criteria and research methods, as well as whether inclusion would be consistent with the decisions made when other discrepancies were resolved.

## Data Abstraction and Development of Evidence Tables

We developed 2 standardized data abstraction forms, 1 for studies that addressed screening for suicide risk and the other for those addressing treatment. The forms were pretested by the 3 authors and modifications were made based on the findings of the pretest. For the studies that met our inclusion criteria, a primary reviewer abstracted relevant information onto the appropriate abstraction form. Another member of the EPC staff entered the information from the abstraction forms into the evidence tables. The primary reviewer for each study checked the accuracy of the evidence table entries and the 2 other authors checked the clarity of the information.

To characterize the quality of the included studies, we rated the internal and external validity for each article using criteria developed by the USPSTF Methods Work Group. ^40^ In addition to these criteria, we further assessed validity as follows: Internal validity considered the proportion of eligible patients who consented to participate as a key factor. External validity focused on the study population's relevance to our population of interest; primary care patients with unidentified suicide risk. For all treatment studies, we assessed several quality factors such as whether inclusion criteria were used and whether attrition between groups was similar; for randomized controlled trials in particular, we further evaluated the adequacy of randomization and allocation concealment, and whether an intention to treat analysis was conducted. For each study, the primary reviewer rated internal and external validity per the above criteria initially. Subsequently, each of these ratings were reviewed by the EPC staff to reach consensus agreement. Finally, the first author reviewed all quality ratings to ensure consistency in the ratings.

Apart from grading individual study quality, we also assessed the aggregate internal and external validity and coherence (agreement of the results of the individual studies) for each of the key questions in the analytic framework.

## Peer Review Process

We conducted an extensive external review of the draft SER. Outside reviewers were representatives of key primary care professional associations that have formal liaison ties to the USPSTF, a representative of the Canadian Task Force on Preventive Health Care, representatives of other professional societies, clinical experts in the area of depression and suicide, staff at the Agency for Healthcare Research and Quality, and representatives of other federal agencies. Appendix A lists the names and affiliations of all peer reviewers.

## Production of This Systematic Evidence Review

The authors worked closely with 2 members of the USPSTF to produce this systematic evidence review (SER) (see Acknowledgments in Appendix A) and presented reports to the full USPSTF in January and May 2002. After feedback from the Task Force and appropriate revisions, we distributed the draft of this review for broad-based external peer review as described above. Following peer review, we made revisions as appropriate, and then presented the final SER to the Task Force in September 2002 for its use in arriving at its final recommendations. We will use the information from this SER to develop a manuscript for publication.