# Appendix B

## Evidence Tables

Glossary

ANOVA | Analysis of Variance
BSSI | Beck Scale for Suicidal Ideation
CBT | Cognitive Behavioral Therapy
CI | Confidence Interval
DBT | Dialectical-Behavioral Therapy
DSH | Deliberate Self-Harm
DSM-III-R | Mental Disorders-III-Revised
ER | Emergency Room
F/U | Follow-up
GP | General Practitioner
GRP(s) | Group(s)
HAM-D | Hamilton Depressive Rating Scale
Hr | Hour
Hx | History
ICU | Intensive Care Unit
INT | Intervention
IM | Intramuscular
ITT | Intention-to-Treat Analysis
K-SADS-P/E | School Age Schedule for Affective Disorders and Schizophrenia, Present and Lifetime Versions
MADS | Montgomery-Asberg Depression Rating Scale
MDD | Major Depressive Disorder
Mg | Milligram
MSSI | Modified Scale for Suicidal Ideation
N | Number
NPV | Negative Predictive Value
NR | Not Reported
NST | Nondirective Supportive Therapy
OCD | Obsessive Compulsive Disorder
OR | Odds Ratio
Outpt | Outpatient
PPV | Positive Predictive Value
Pts | Patients
RR | Relative Risk
RSQ | Risk of Suicide Questionnaire
Rx | Prescription
SA | Suicide Attempt
SBFT | Systemic Behavioral Family Therapy
SD | Standard Deviation
SI | Suicidal Ideation
SIQ | Suicide Ideation Questionnaire
SIQ-JR | Suicide Ideation Questionnaire-Junior High School Version
SPS | Suicide Probability Scale
SSI | Scale for Suicide Ideation
Tx | Treatment
VA | Veterans Administration
Wk | Week
Wkly | Weekly

Table 1 Screening for Suicide Risk

Author, Year | Setting | Inclusion/Exclusion Criteria (for those screened) | Population Characteristics | Screening Method | Criterion Standard | Screen and Criterion Standard Administered Independently? | Test Characteristics | Adverse Effects of Test? | Conclusion(s) | Internal/External Validity | Overall Quality | Limitations
| | | | | | Interpreted Blind to Screen?
Olfson et al., 1996 ^23^ | Primary care clinic in medical setting | Attendance at primary care clinic affiliated with one of 3 medical centers. Demographic information is reported for all 3 grps. Test characteristics of suicide items collected from and reported for only 1 grp. | N=2,749 | Self-administered 62-item psychiatric case-finding instrument with three items related to SI. Screening positive involved answering yes to any 1 of 3 items involving the past month: feeling suicidal?, wished you were dead?, and thoughts of death? | Nurse administered face-to-face structured interview conducted immediately prior to medical visit (when self-administered screen completed) in which pt responded yes to following question: In the last month, did you have a plan to kill yourself? | Yes | Test 1: Feeling suicidal. Positive test = Yes (n=33). Sensitivity 83%; specificity 98%. PPV=30.3 | Not reported | Self-reported “feeling suicidal” item corresponded closely with acknowledged plans to attempt suicide | Fair/Good | Good | Only 46% of eligible pts approached across the 3 centers agreed to participate.
| | | % female: 68 | | | Yes | Test 2: Wished you were dead. Positive test = Yes (n=79). Sensitivity 92%; specificity 93%. PPV=13.9 | | | | | No data on physician detection of suicide in routine practice, so unclear about possible value of screening for this symptom.
| | | Age range: 18–70 years (two-thirds between 26 and 55) | | | | Test 3: Thoughts of death. Positive test = Yes (n=202). Sensitivity 100%; specificity 81%. PPV=5.9.A6 | | | | | Limited data on suicide attempt and no data on suicide completion.
| | | 71% Caucasian | | | | | | | | | Unclear what degree of risk endorsing a suicide plan within the past month details - is this a reasonable “gold standard” for moderate-to-severe risk?
| | | 21% Black
| | | 8% other
Horowitz et al., 2001 ^47^ | ER | Children and adolescents presenting to ER in tertiary care center in Boston with chief complaint related to a psychiatric issue per triage nurse | N=144 | RSQ administered by triage nurse in ER | SIQ administered by member of pyschology team. If <10th grade got SIQ-JR. | Yes | Conducted analyses on a 4-item subscale. | Not reported | A four-item screening test administered in the ER setting had sensitivity of 98%, a specificity of 37%, a PPV of 55% and a NPV of 97% | Good/Fair-Poor | Good | ER patients with suspected psychiatric issues who are probably not reflective of clinic population.
| | | % females=54 | | Cut-off ≥41 for SIQ; ≥31 for SIQ-JR | Yes | 1) Are you here because you tried to hurt yourself? | | | | | Focused on adolescent showing up with suicide-related issues.
| | | Age range: “75% between 11 and 16 years.” Mean ± SD age = 13.6 years (2.48) | | | | 2) In the past week, have you had any suicidal thoughts?
| | | 49% Caucasian | | | | 3) Have you ever attempted suicide in the past?
| | | 26% Black | | | | 4) Has something very stressful happened in the past 3 weeks?
| | | 15% Latino | | | | Sensitivity 0.98; specificity 0.37;
| | | 1% Asian | | | | PPV -0.55;
| | | | | | | NPV - 0.97

Table 2 Evidence Table. Treatment of Suicide Risk

Author, Year | Selection of Population | Definition of Intervention and Study Groups | Characteristics of Enrolled Population | Primary Outcome: Definition and Results | Secondary Outcome: Definition and Results | Intention-to-Treat Analysis (Yes/No) | Overall Quality: Internal/External Validity | Conclusions | Comments and Limitations
Montgomery et al., 1994 ^63^ | Recruitment setting: Psychiatric clinic | INTERVENTION: 60 mg fluoxetine twice a week | INTERVENTION | Number of suicide attempts in 6-month period. Because several patients may have had more than 1 suicide attempt during the study, the denominator is not the number in each group as the authors presented. | NR | No | Internal Validity: Poor | Fluoxetine was not useful for suicide prevention. | Subtherapeutic dosing of fluoxetine, only 120 mg per week
RCT | Age range: NR | CONTROL: placebo twice a week | Total N = 54 | INTERVENTION: N = 18 | | | External Validity: Poor | | No demographic information or psychiatric information was available
| Eligibility: Patients with a history of 2 or more suicide attempts | Tx setting: Psychiatric clinic | Age: Mean = NR | CONTROL: N = 18 | | | | | Results not clearly specified; proportion of patients with a repeat SA not clear
| Exclusion criteria: No current major depression according to DSM-III-R | Tx duration: 6 months | Female: NR | No difference between intervention and control | | | | | Population not representative of patients with unidentified suicide risk
| | F/U duration: 0 months | Prior SA: NR
| | | Psych comorbidity: NR
| | | CONTROL
| | | Total N = 53
| | | Age: Mean = NR
| | | Female: NR
| | | Prior SA: NR
| | | Psych comorbidity: NR
Rudd et al., 1996 ^62^ | Recruitment setting: Potential patients referred from 2 mental health clinics, 1 emergency room, and 1 in-patient psychiatric unit. | INTERVENTION: Outpt intensive structured group-treatment in day hospitalization setting 9 hrs daily for 2 weeks (10 weekdays). Patients received 2-hr wkly support groups while waiting for group to accumulate. | INTERVENTION | SI as measured by MSSI | Likelihood of suicide as measured by SPS | No | Internal validity: Poor | No differences in SI or likelihood of suicide between patients enrolled in a 2 week intensive day-treatment program vs. treatment as usual. | Study focused primarily on a male military population
RCT | Age range: Mean = 22 ± 2.3 | CONTROL: Usual care (combination of inpt and outpt care that was not well-defined or measured). | Total N = 143 | INTERVENTION: mean 3.1 ± 9.0 | Intervention: mean 55.6 ± 13.2 | | External validity: Poor | | 20% of day-treatment intervention group required hospitalization
| Eligibility: Suicide attempt, mood disorder with concurrent SI, or episodic substance use with SI. | Tx setting: Psychiatric outpatient day-hospital | Age: NR | Control: mean 0.8 ± 3.8 | Control: mean 57.4 ± 10.4 | | | | No measures of treatment received after the 2 wk intervention
| Exclusion criteria: Psychosis, thought disorder, personality disorder rendering outpatient group therapy inappropriate. | Tx duration: 2 weeks | Female: 32 | Repeated measures ANOVA: No differences between groups | Repeated measures ANOVA: No differences between groups | | | | No attempt to measure treatment as usual (control)
| | F/U duration: 1 year | Prior SA: 12.7% by cutting | | | | | | High attrition rate
| | | Psych comorbidity: report no statistical differences between groups | | | | | | Low power
| | | CONTROL
| | | Total N = 121
| | | Age: NR
| | | Female: 15
| | | Prior SA: 4% by cutting
| | | Psych comorbidity: report no statistical differences between groups
Brent et al., 1997 ^92^ | Recruitment setting: Psychiatric clinic. One third recruited by advertising and 2/3 recruited from patients referred by self, parent, or professionals. | INTERVENTION #1 | INTERVENTION #1: 12–18 sessions of CBT | Proportion with SI score >4, which is suicidality with a plan or an attempt as measured on K-SADS-P/E. | Proportion meeting DSM-III-R critieria for MDD from the K-SADS-P/E | Yes | Internal validity: good | Adolescents age 13–18 with MDD who receive CBT show statistically greater improvements in depression at 16 weeks than adolescents receiving SBFT or NST. Although adolescents in all 3 groups show less SI at 16 weeks, there are no differences between groups. | The adolescents at highest risk for suicide may be missed in this study because recruitment setting did not include emergency rooms.
RCT (intermediate outcome only) | Age range: 13–18 | Total N = 37 | INTERVENTION #2: 12–18 sessions of SBFT | INTERVENTION #1: 8.6% | Intervention #1: 17.1% | | External validity: fair-good
| Eligibility: Met criteria for MDD defined as > or = to 13 on the Beck Depression Inventory, normal intelligence (not defined), and living with at least one parent or guardian. | Age: Mean 15.7 (1.3) | CONTROL: 12–18 sessions of NST | INTERVENTION #2: 6.5% | Intervention #2: 32.3%
| Exclusion criteria: Psychosis, OCD, eating disorder, bipolar illness, current substance abuse, chronic medical illness, pregnancy. | Female: 75.7% | Tx setting: Psychiatric clinic | CONTROL: 15.2% | Control: 42.4%
| | Prior SA: 21.6% | Tx duration: 12–16 weeks | Random effects regression analysis: No statistically significant difference among 3 groups, although all showed significant decreases in SI compared to baseline (McNemar Chi square, p < 0.001). | Chi square: Trend for differences among the 3 grps (P = .07), with a pairwise difference between Intervention#1 and Control (P = .02)
| | Psych comorbidity: 37.2% anxiety | F/U duration: Immediately after treatment phase
| | INTERVENTION #2
| | Total N = 35
| | Age: Mean 15.4 (1.4)
| | Female: 77.1%
| | Prior SA: 22.9%
| | Psych comorbidity: 28.6% anxiety
| | CONTROL
| | Total N = 35
| | Age: Mean 15.7 (1.5)
| | Female: 74.3%
| | Prior SA: 25.7%
| | Psych comorbidity: 28.6% anxiety
Bateman and Fonagy, 1999, ^55^ 2001 ^56^ | Recruitment setting: Psychiatric clinic (patients already identified as needing psychiatric evaluation and referred by outside clinician) | INTERVENTION: Psychoanalytically-oriented partial hospitalization | INTERVENTION | % with suicide attempts within prior 6 mo's measured by self-report at end of the 18 mo treatment | % with suicide attempts within prior 6 months measured by self-report at end of the 36 months (18 months after treatment period ended) | No | Internal Validity: Fair (no intention to treat analysis; no blinded outcome [data was self-report, then attempt were made to cross-check with hospital records]) | Psychoanalytically-oriented partial hospitalization decreased number of suicide attempts relative to usual care | 73% of those eligible were enrolled
RCT | Age range: 16–65 years | CONTROL: Usual care, consisting of general outpatient psychiatric services without formal psychotherapy | Total N = 19 | INTERVENTION: 5.3% | INTERVENTION: 18% | | External Validity: Poor (focus on borderline personality disorder patients, and patients were already identified as requiring psychiatric evaluation, so may not be generalizable to unidentified primary care patients) | Psychiatric outpatient treatment for borderline personality disorder patients at moderate-high risk to harm selves. | Small sample size
| Eligibility: Borderline personality disorder (as determined by Structured Clinical Interview for DSM-III-R and by Diagnostic Interview for Borderline Patients score ≥ 7) | Medications were prescribed as needed | Age: Mean = 30.3 ± 5.86 | CONTROL: NR, but figure suggests ~40% | CONTROL: 63% | | | | Intervention had many facets, making it hard to know what the key component(s) was (were).
| Exclusion criteria: Bipolar disorder, current substance abuse, psychotic disorder, mental impairment, organic brain disorder | Tx setting: Partial hospitalization on psychiatric unit or outpatient psychiatric clinic | Female: 68% | Mann Whitney test: P < 0.001 | Fisher exact test: P < 0.004 | | | | Usual care could be quite variable
| | Tx duration: 18 mo's | Prior SA: 94.7% | | | | | | Intervention group continued twice weekly group analytic therapy after formal treatment period ended, potentially confounding 36 month follow-up outcome results
| | F/U duration: 18 mo's (note that INTERVENTION group continued group analytic therapy twice per week during follow-up) | Psych comorbidity: > 70% (primarily mood and anxiety disorders) | | | | | | Population not representative of patients with unidentified suicide risk
| | | CONTROL
| | | Total N = 19
| | | Age: Mean = 33.3 ± 6.60
| | | Female: 47%
| | | Prior SA: 70–75%
| | | Psych comorbidity: > 62% (primarily mood and anxiety disorders)
Battaglia et al., 1999 ^66^ | Recruitment setting: Psychiatric emergency service | INTERVENTION: Low dose IM fluphenazine decanoate (antipsychotic): 2.5 mg/month | INTERVENTION | Change in rate of serious DSH behaviors/month measured as self-report at 6 months using Parasuicide History Inventory | NR | No | Internal Validity: Fair (not intention to treat analysis; only 26% of those who were eligible were enrolled) | No significant difference between intervention and control groups at 6 months, although the trend favors low dose fluphenazine decanoate. Would need 64 patients in each group to be powered to show a significant difference. | 26% of those eligible were enrolled
RCT | Age range: 18–65 years | CONTROL: Ultra-low dose IM fluphenazine decanoate:1.5 mg/ month | Total N = 30 | INTERVENTION: -0.16 ± 0.19 | | | External Validity: Poor | Both groups had significant decreases in suicidal behaviors relative to pre-randomization rates. | Small sample size
| Eligibility: Suicide attempt within 30 days and ≥ 2 prior suicide attempts | Tx setting: Psychiatric emergency service | Age: Mean = 29.7 ± 5.9 | CONTROL: -0.06 ± 0.22 | | | | | High degree of comorbid substance abuse/dependence and borderline personality disorder also may make this population less representative of unidentified patients at suicide risk in primary care setting
| Exclusion criteria: Psychotic illness; current or expected treatment with psychotropic medications; allergy to fluphenazine; history of tardive dyskinesia or neuroleptic malignant syndrome. | Tx duration: 6 months | Female: 43% | Mann-Whitney test: NS (P = 0.1459) | | | | | Population not representative of patients with unidentified suicide risk
| | F/U duration: none | Prior SA: 100%
| | | Psych comorbidity: > 43% with substance abuse or dependence; > 37% with borderline personality disorder
| | | CONTROL
| | | Total N = 28
| | | Age: Mean = 31.2 ± 8.2
| | | Female: 44%
| | | Prior SA: 100%
| | | Psych comorbidity: > 36% with substance abuse or dependence; > 29% with borderline personality disorder
Evans et al., 1999 ^64^ | Recruitment setting: General inpatient medical facility | INTERVENTION: Card offering 24-hour crisis telephone consultation with on-call psychiatrist for 6 months | INTERVENTION | % with repeat DSH identified through hospital case registry | # of repeat DSH episodes identified through hospital case registry | Yes | Internal Validity: Fair | Providing a card offering emergency telephone support to patients following medical admission for DSH does not appear to influence overall repetition rates. | Routine health service information systems used may underestimate repeat DSH
RCT | Age range: “Adults” | CONTROL: Usual care | Total N = 417 | INTERVENTION: 16.8% | INTERVENTION: Mean = NR | | External Validity: Poor | Subgroup analyses suggested that response to intervention differed by history of DSH; for those with a previous DSH, the odds of repeating DSH were higher in the intervention group (OR 1.85, 95%CI 1.14, 3.03), while for those with no prior DSH in the intervention, the odds of repeating DSH tended to be higher in the control group (OR 0.64, 95%CI 0.34, 1.22) | Detection of DSH by self-laceration is less reliable; case registry is better with overdoses
| Eligibility: All adults admitted after DSH to 2 of 3 general hospitals in Bristol, England AND referred for psychiatric evaluation. | Tx setting: Outpatient with psychiatric availability | Age: Mean = 32.9 ± 12.9 | CONTROL: 14.4% | CONTROL: Mean = NR | | | | Findings were confined to DSH patients admitted overnight to the hospital and cannot be generalized to all DSH patients
| Exclusion criteria: High risk of not using intervention appropriately or of dangerousness to self or others. | Tx duration: 6 months | Female: 58% | OR = 1.20 (95% CI: 0.82, 1.75) | Chi square: “not significant” | | | | Population not representative of patients with unidentified suicide risk
| | F/U duration: 0 months | Prior SA: 12.5% | P = NR
| | | Psych comorbidity: 87%
| | | CONTROL
| | | Total N = 410
| | | Age: Mean = 33.8 ± 13.1
| | | Female: 53%
| | | Prior SA: 8.0%
| | | Psych comorbidity: 87.1%
Guthrie et al., 2001 ^61^ | Recruitment setting: Emergency room | INTERVENTION: 4 sessions of interpersonal psychotherapy, 50 minutes weekly, delivered by nurse therapists | INTERVENTION | Repetition of DSH measured as self-report at 6 months (intention to treat) | Number of reported episodes of self-harm | Yes (for primary outcome) | Internal Validity: Fair-good | 4 sessions of interpersonal psychotherapy decreased both repeated self harm attempts (ITT analysis) and SI (not ITT analysis) relative to usual care 6 months after entry into the study. | 51% of eligible patients were enrolled, so those enrolled were of a moderate-high severity
RCT | Age range: 18–65 years | CONTROL: Usual care | Total N = 58 | INTERVENTION: 9% | INTERVENTION: Mean = 0.6(95% CI 0.3–0.9) | | External Validity: Poor | | Those who refused were at greater suicide risk, more likely to have a history of DSH, to have left a suicide note, and to express a wish to die
| Eligibility: Presented to emergency room with deliberate self-poisoning | Tx setting: Patient's home | Age: Mean = NR by group; of total number of participating subjects, means age was 31.2 years ± 1.5 | CONTROL: 28% | CONTROL: Mean = 1.8 (95% CI 0.6–3.0) | | | | Outcome assessment not blinded (self-report)
| Exclusion criteria: Requiring inpatient psychiatric treatment; not be registered with a general practitioner; living outside hospital catchment area; serious medical illness. | Tx duration: 1 month | Female: 43% | Absolute rate difference: = 19.3% (95% CI: 8.6%, 30.0%) | Mean difference = NS | | | | Population not representative of patients with unidentified suicide risk
| | F/U duration: 6 months (including the 1 month of treatment) | Prior SA: 57% | P = 0.009
| | | Psych comorbidity: 48%
| | | Baseline severity of suicidal thoughts: 15.9 (9.9) as measured by BSSI
| | | CONTROL
| | | Total N = 61
| | | Age: Mean = NR by group; of total number of participating subjects, mean age = 31.2 years ± 1.5
| | | Female: 46%
| | | Prior SA: 62%
| | | Psych comorbidity: 61%
| | | Baseline severity of suicidal thoughts: 14.3 (10.8) as measured by BSSI
Koons et al., 2001 ^57^ | Recruitment setting: 1 Women Veterans primary care clinic, Veterans Counseling Centers, and other Veterans medical centers. | INTERVENTION: Dialectical Behavior Therapy, medications as needed | INTERVENTION | % with DSH during previous 3 months measured by self-report | SI as measured by the BSSI | No | Internal Validity: Fair. Not intention-to-treat analysis; multiple tests increase risk of type 1 error; randomization process not described; small sample size | DBT was not superior to usual care in decreasing DSH. DBT was superior to usual care in decreasing SI scores. | Small sample size.
RCT | Age range: adults (needed to be veterans) | CONTROL: Usual care (60 minutes of weekly individual therapy with VA clinician, supportive and psychoeducational groups, medications as needed) | Total N = 10 | INTERVENTION: 10% (1/10; a decrease from 50% at baseline) | INTERVENTION: Mean = decrease by 10 points | | External Validity: Poor. Access to care unfettered in this VA system. Patients seen not representative of primary care. | | Inconsistent results with regard to decreasing depressive symptoms. Using Beck Depression Inventory (self-report), there was a significantly greater decrease in depressive symptoms than with usual care (one-way ANOVA, P = 0.026). Using the Hamilton Depression Rating Scale (administered by interviewer), there was no significantly greater decrease for DBT group vs. usual care (one-way ANOVA, P = 0.11)
| Eligibility: Women veterans with DSM-III-R criteria for Bordeline Personality Disorder | Tx setting: Veterans psychiatric outpatient clinic | Age: Mean = 34.5 ± 7.5 | CONTROL: 20% (2/10;a decrease from 30% at baseline) | CONTROL: Mean = decrease by 4.1 points | | | | Usual care group received intensity and quality of treatment likely greater than most usual care groups, and most usual care therapists had treatment orientations with similarities to DBT, each of which might make differences more difficult to show.
| Exclusion criteria: Schizophrenia, bipolar disorder, substance dependence, and antisocial personality disorder. | Tx duration: 6 months | Female: 100% | No significant difference between the rates. The difference between the proportions going from any DSH to no DSH was suggestive of an effect for the intervention group (P = 0.07), while there was no suggestion of an effect for the control group (P = 1.00) | Two-way repeated measures ANOVA indicated that DBT decreased significantly more than control (P <0.05)
| | F/U duration: none | Prior SA: unclear--75% of whole group had a lifetime history of DSH, and proportions between intervention and control groups described as insignificant
| | | Psych comorbidity: NR
| | | CONTROL
| | | Total N = 10
| | | Age: Mean = 35.4 ± 6.9
| | | Female: 100%
| | | Prior SA: unclear--75% of whole group had history of DSH, and proportions between intervention and control groups described as insignificant
| | | Psych comorbidity: NR
Motto and Bostrom, 2001 ^65^ | Recruitment setting: Nine psychiatric inpatient facilities in San Francisco | INTERVENTION: Contact in the form of regular communications using short letters expressing concern and support from the hospital interviewer. Patient could respond using a self-addressed envelope but was not required to respond. Letters were sent once per month for 4 months, every 2 months for 8 months, and then every 3 months for 4 years. | INTERVENTION | 1) % with suicide as cause of death 5 years after discharge | Difference in survival over time since discharge using Kaplan-Meier probabilities | Yes | Internal Validity: Fair | Continuing to remain in contact with individuals who are at risk of suicide and who refuse therapy is effective for reducing suicide completion for up to 2 years post-discharge but not afterwards. | Appears to be a convenience sample from the 9 facilities
RCT | Age range: NR | CONTROL: No further active involvement post-discharge | Total N = 389 | Identified through coroner's records, death certificates, clinical sources, and family members | Intervention group had fewer suicides than control group at 2 years (P = 0.043) but difference disappeared at 5 years post-discharge. | | External Validity: Poor | | Not clear whether the study was powered to detect a difference in completed suicides over the 5 and 15 year follow-up period
| Eligibility: Persons admitted for depressive or suicidal illnesses. | Tx setting: Outpt | Age: Mean = 34.4 | INTERVENTION: 3.9% | | | | | Not a well-controlled study--no control for events occurring subsequent to discharge that may have influenced suicide risk
| Exclusion criteria: Patients who continued with therapy for at least 30 days post-discharge, with therapy provided by psychiatrists, psychologists, social workers, or pastors. | Tx duration: 5 years | Female: 58% | CONTROL: 4.6% | | | | | Population not representative of patients with unidentified suicide risk
| | F/U duration: up to 15 years | Prior SA: NR | 2) % with suicide as cause of death 15 years after discharge
| | | Psych comorbidity: NR | INTERVENTION: 6.4%
| | | CONTROL | CONTROL: 5.7%
| | | Total N = 454
| | | Age: Mean = 32.8
| | | Female: 54%
| | | Prior SA: NR
| | | Psych comorbidity: NR
Wood et al., 2001 ^44^ | Recruitment setting: Psychiatric clinic and inpatient facility | INTERVENTION: Initial assessment phase, attendance in 6 “acute” group sessions, followed by weekly group sessions in a “long-term” group until young person feels ready to leave. | INTERVENTION | Proportion who report 2 or more episodes of DSH after randomization (“repeaters”) | SI at 6 months as measured by SIQ (not intention to treat) | Yes | Internal validity: Fair | Intervention did not decrease mean number of episodes of DSH, but did decreased proportion of patients who reported repeated (2 or more) episodes of DSH. | Reliance on self-report measures of DSH
RCT | Age range: 12–16 years | CONTROL: Usual care (not well defined or measured) | Total N = 32 | INTERVENTION: 6% | INTERVENTION: Mean decrease = 47.3 | | External validity: Poor | | Small sample size
| Eligibility: Referred after episode of DSH and reported at least 1 other episode of DSH in past year | Tx setting: NR | Age: 14.2 (1.1) | CONTROL: 32% | CONTROL: | | | | Significant OR associated with wide CI
| Exclusion criteria: Suicide risk precluded outpatient treatment, unable to attend or benefit from group therapy, psychosis, overdose on alcohol or accidental overdose on illicit drugs. | Tx duration: Median of 8 group sessions over 6 months (range 0–19) | Female: 25 | Cox regression controlling for number of episodes of DSH prior to randomization: OR = 6.3 [95% CI 1.4–28.7] | Mean decrease = 39.7 | | | | Findings would need to be confirmed in larger studies
| | F/U duration: 7 months post-randomization | Prior SA: # of previous episodes of DSH = 4.1(2.3) | | Mean difference = NS (7.5, 95%CI -18.8 to 33.9) | | | | Population not representative of patients with unidentified suicide risk
| | | Psych comorbidity: 27 with hx of MDD
| | | CONTROL
| | | Total N = 31
| | | Age: 14.3(2.1)
| | | Female: 24
| | | Prior SA: # of previous episodes of DSH = 4.2(2.6)
| | | Psych comorbidity: 25 with Hx of MDD
Bennewith et al., 2002 ^58^ | Recruitment setting: Case register for DSH covering a particular catchment area; subjects must be registered with a GP | INTERVENTION: GP received a letter informing them of a DSH episode, a letter to forward to the patient (at GP's discretion) inviting patient to make an appointment to consult, and guidelines on assessment and management of DSH for GP to use in consultations. | INTERVENTION | % with repeated DSH as indicated by case register | Mean days to first repeat episode as indicated by case register | Yes | Internal Validity: Fair-good (only 58% of intervention group sent letter to patient within the 12 month period, compared to 15% of control group who initiated contact with patient) | Identification to a GP practice of a patient's DSH episode and related recommendations, including management guidelines for a subsequent DSH consultation and provision of a letter inviting a DSH patient to consult, did not reduce the incidence of DSH. | This report is the only published study of an intervention based in primary care
RCT | Age range: 16–95 years | CONTROL: Usual care | Total N = 964 | INTERVENTION: 21.9% | INTERVENTION: Mean = 104.9 | | External Validity: Good | | Assessment of outcome was blinded
| Eligibility: Patients with a new episode of DSH identified from a case register in weekly report from local hospitals' accident and emergency departments, and those individuals from general practices which had agreed to participate in study were identified. | Tx setting: Primary care | Age: Mean = 32.3 ± 13.0 | CONTROL: 19.5% | CONTROL: Mean = 109.5 | | | | 60% of patients from each group attended a GP appointment within 6 weeks of index episode, most within 2 weeks
| General practices agreeing to be randomized (60% of those eligible) were the unit of randomization. | Tx duration: One time receipt of above information by mail | Female: 60.3% | OR = 1.17 (95% CI: 0.94, 1.47) | Hazard ratio = 1.15 (95% CI: 0.94, 1.42) | | | | For those with a history of DSH, OR for the intervention = 0.57 (95% CI 0.33–0.98), suggesting benefit for the intervention
| Exclusion criteria: Substance use not felt to be DSH; homeless; patient requested no one be informed of episode; DSH secondary to psychosis; DSH managed entirely in primary care (so did not require visiting a hospital or emergency department). | F/U duration: 12 months | Prior SA: 13.9% | P = 0.16 | P = 0.17 | | | | For those with no history of DSH, OR = 1.32 (95% CI 1.02, 1.70), suggesting a harmful effect from the intervention
| | | Psych comorbidity: NR | | | | | | The intervention was of minimal intensity
| | | CONTROL
| | | Total N = 968
| | | Age: Mean = 32.8 ± 13.5
| | | Female: 57.3%
| | | Prior SA: 11.4%
| | | Psych comorbidity: NR
Montgomery et al., 1978 ^91^ | Recruitment setting: NR | INTERVENTION 1: Mianserin 60 mg | INTERVENTION 1 | Intermediate outcome only | Decrease in SI was demonstrated for comparison between mianserin and amitriptyline using the MADS only (not HAM-D) | No | Internal Validity: Poor | Drug effect demonstrated for comparison between mianserin to amitriptyline using the MADS only, not the HAM-D | Only SI assessed, not suicide attempts
Cohort | Age range: NR | INTERVENTION 2: Amitriptyline 150 mg | Total N = 50 | | INTERVENTION 1: Mean = ~ 11.0 | | External Validity: Poor | | Very small sample size
| Eligibility: Primary depressive illness; 30 of 80 patients were from an ongoing study comparing amitriptyline to mianserin | INTERVENTION 3: Maprotiline 150 mg | Age: Mean = 44.4 ± 2.1 | | INTERVENTION 2: Mean = ~ 5 | | | | Very little explanation of study methods and analysis
| Exclusion criteria: NR | Tx setting: Inpatient | Female: NR | | INTERVENTION 3: Mean = ~ 6 | | | | Population not representative of patients with unidentified suicide risk
| | Tx duration: 4 weeks | HAM-D: 24.6 ± 0.8 | | t test (intervention 1 vs. intervention 2) = 2.8
| | F/U duration: 0 weeks | MADS: 17.2 ± 0.6 | | P = < 0.01
| | | INTERVENTION 2 | | t test (intervention 1 vs. intervention 3) = 1.8
| | | Total N = 15 | | P = < 0.10
| | | Age: Mean = 43.2 ± 3.4
| | | Female: NR
| | | HAM-D: 22.1 ± 0.9
| | | MADS: 16.5 ± 0.5
| | | INTERVENTION 3
| | | Total N = 15
| | | Age: Mean = 41.5 ± 3.7
| | | Female: NR
| | | HAM-D: 23.4 ± 1.1
| | | MADS: 15.9 ± 1.2
Pfeffer et al., 1994 ^89^ | Recruitment setting: Inpatient mental health facility and community setting | INTERVENTION: Treatment post-hospitalization measured by self-report, parent report, school and clinic records | INTERVENTION | No association between annual rate of combined treatment services and occurrence of 1st suicide attempt. | Numbers of suicidal episodes (SI or attempt) | No | Internal validity: Fair | No association between treatment and SI or attempts. | Naturalistic design limits ability to address treatment questions
Cohort | Age range: 4.7–14.7 years at initial recruitment [mean 10.5 (SD 1.8)] | CONTROL: Natural history of community sample | Total N = 69 | No association between specific type of service and time to first attempt. | INTERVENTION: N = 38 (55.1%) | | External validity: Poor | | Sicker patients most likely received more treatment
| Eligibility: 53 psychiatric inpatients with and 16 without SI or attempt in previous 6 months, and 64 nonpatients selected from general community matched by demographic factors | Tx setting: Multiple | Age: NR | Rx drugs associated with shorter interval to first attempt (RR 17.03, 95% CI 3.33–87.1, P < 0.001), which likely reflects a more severely ill population. | CONTROL: N = 22 (34.4%) | | | | Population not representative of patients with unidentified suicide risk
| Exclusion criteria: NR | Tx duration: Varied | Female: NR (27% overall) | First suicidal episodes in patients most prevalent in first 2 yrs of F/U while community sample had slow gradual increase over full F/U interval. | No analysis reported
| | F/U duration: 7.16 ± 1.0 years | Prior SA: NR
| | | Psych comorbidity: All
| | | CONTROL
| | | Total N = 64
| | | Age: NR
| | | Female: NR (27% overall)
| | | Prior SA: 1.6% in previous 6 months
| | | Psych comorbidity: 44
Rotheram-Borus et al., 2000 ^90^ | Recruitment setting: Emergency room | INTERVENTION: Emergency room staff received training, patients and mothers watched a 20-minute “soap opera” videotape conveying treatment expectations, and bilingual crisis therapist discussed videotape, provide 1 therapy session and contract for outpatient F/U treatment. | INTERVENTION | Number of suicide attempts measured by self-report, mother's report, and hospital records | Proportion of patients with Beck Depression Inventory scores in the clinical range at 18 months | No, though used multiple imputation to account for missing data | Internal validity: Fair | Emergency room intervention was not associated with decreased suicide behaviors. | Primarily Latino females in an urban emergency room
Cohort | Age range: 12–18 years | CONTROL: Standard emergency room care and outpatient referral. | Total N = 65 | INTERVENTION: 6 | INTERVENTION: 4.9% | | External validity: Poor | Emergency room intervention was associated with decreased depression and increased number of outpatient F/U sessions (mean of 3.8 more sessions). | Small sample size for main outcome of suicide attempt
| Eligibility: Female patients who had attempted suicide, were not hospitalized for more than 1 week, and were not referred to hospitals outside of the region | Tx setting: Emergency room | Age: 14.9 (SD = 1.4) | CONTROL: 11 | CONTROL: 10.1% | | | | Population not representative of patients with unidentified suicide risk
| Exclusion criteria: No parent or family; low intelligence (not defined) | Tx duration: One emergency room encounter | Female: All | No statistically significant difference | Multivariate linear regression: Beta = -.546 (P < .01)
| | F/U duration: 18 months | Prior SA: 31.8%
| | | Psych comorbidity: 59% (depression)
| | | CONTROL
| | | Total N = 75
| | | Age: 14.9 (SD = 1.5)
| | | Female: All
| | | Prior SA: 29.7%
| | | Psych comorbidity: 60% (depression)
Coryell et al., 2001 ^87^ | Recruitment setting: 5 academic medical centers | TREATMENT EVALUATED: Medication use at time of case's suicide completion or attempt | COMPLETED SUICIDES | Medication use at time of suicide completion | Medication use at time of suicide attempt | NR | Internal Validity: Fair | Lithium was not protective for preventing suicide completion or attempts. | Deaths detected when attempts to recontact failed, confirmed with death certificate and medical record
Cohort | Age range: 17 years or older | Tx setting: Outpt | Total N = 15 | COMPLETED SUICIDES: | ATTEMPTED SUICIDES: | | External Validity: Fair-Poor | | Questionable comparability between cases and controls
| Eligibility: Cohort of patients treated for major affective disorders. From this cohort, a case-control study was designed with two case groups-- suicide completers and suicide attempters. Controls were matched to cases on level of treatment at the same point in the case's follow-up period, sex, polarity at intake, lifetime substance abuse, and prior SA history. | Cohort enrolled: 1978-1981 | Age: Mean = 39.1 ± 17.7 | TCA: 40.0% | TCA: 63.4% | | Methods were not very clear. Follow-up occurred over approx 13 yrs, pts may have completed a Psychiatric Status Rating weekly. | | Population not representative of patients with unidentified suicide risk
| Exclusion criteria: NR | F/U duration: ranged from 45.6 ± 36.5 in controls for suicide completers to 164.5 ± 75.6 for controls of suicide attempters | Female: 46.7% | MAOI: 13.3% | MAOI: 22.0%
| | | Prior SA: 26.7% | SSRI: 6.7% | SSRI: 4.9%
| | | Psych comorbidity* = 40.0% | Lithium: 40.0% | Lithium: 22.0%
| | | CONTROLS (COMPLETERS) | CONTROLS FOR COMPLETERS | CONTROLS FOR ATTEMPTERS
| | | Total N = 15 | TCA: 46.7% | TCA: 80.5%
| | | Age: Mean = 40.2 ± 13.0 | MAOI: 0% | MAOI: 14.6%
| | | Female: 40% | SSRI: 0% | SSRI: 0%
| | | Prior SA: 13.3% | Lithium: 53.3% | Lithium: 19.5%
| | | Psych comorbidity* = 53.3% | Lithium (case vs control): | Lithium (case vs control):
| | | ATTEMPTED SUICIDES | McNemar Chi square: 0.667 | McNemar Chi square: 0.067
| | | Total N = 41 | P = 0.41 | P = 0.80
| | | Age: Mean = 33.5 ± 12.5 | Statistical results given for lithium only | Statistical results given for lithium only
| | | Female: 80.5%
| | | Prior SA: 22.0%
| | | Psych comorbidity* = 0%
| | | CONTROLS (ATTEMPTERS)
| | | Total N = 41
| | | Age: Mean = 38.2 ± 13.4
| | | Female: 70.7%
| | | Prior SA: 14.6%
| | | Psych comorbidity* = 0%
Raj et al., 2001 ^88^ | Recruitment setting: Intensive care unit of a general hospital | INTERVENTION: 10 sessions over a 2–3 month period where sessions included cognitive behavioral methods such as guided discovery and Socratic questions, verbal challenge, downward arrow method, activity scheduling, graded task assignment, cognitive restructuring, guided imagery, retribution and decatastrophising, distraction, behavioral and homework methods, diary maintenance, breathing exercises, suicidal contracts, problem-solving skills training, and behavioral counseling to significant others. Monthly letters sent for 2–3 months with booster sessions (1 to 5 sessions) as necessary. | Patients were allocated to intervention and control sequentially upon admission to the ICU | % with repeats SAs | SI using difference in SSI) scores between baseline and 2–3 months post-discharge. | No | Internal Validity: Poor | Flexible use of therapeutic methods addressing the individual's needs is effective with this population. Problem solving skills training, combined with cognitive and behavioral methods were successful at reducing suicide attempts and completions. | Non-randomized study
Cohort | Age range: 16–50 years | CONTROL: Routine medical treatment with an option to attend therapy sessions. Reminders sent for 2 months post-discharge about availability of therapy. | BOTH GROUPS COMBINED | INTERVENTION: 0% (n = 0) | INTERVENTION: Mean = 15.0 ± 7.79 | | External Validity: Poor | | Intervention group received personalized therapy but control group could receive therapy as well without control in the analysis
| Eligibility: Patients who attempted suicide for the first or second time by overdosing on drugs or pesticides, who also had anxiety or depression (mild, moderate, or severe). | Tx setting: NR | Total N = 40 (20 in INT and 20 in CONTROL) | CONTROL: 5% (n = 1) | CONTROL: Mean = 2.75 ± 6.09 | | | | Intervention group had lower educational attainment and salary, and higher rates of family history of psychiatric illness (65% vs. 5% in control group)
| Exclusion criteria: Those who scored <20 on the Mini-Mental State Examination with psychosis, dysthymia, bipolar affective disorder, obsessive compulsive disorder, eating disorder, alcohol dependence or abuse of other psychoactive drugs, personality disorders (paranoid, schizoid, dissocial. | Tx duration: 2–3 months | Age range: no mean given; 85% were between 16–30 years of age | | t test = NR | | | | Population not representative of patients with unidentified suicide risk
| | F/U duration: 0 months | Female: 57.5% | | P = 0.00
| | | Prior SA: NR
| | | Psych comorbidity: 22.5%