# Appendix A

## Acknowledgments

This study was supported by Contract 290-97-0011 from the Agency of Healthcare Research and Quality (Task No. 3). We acknowledge at AHRQ the continuing support of Jacqueline Besteman, JD, MA, Program Officer for the Evidence-based Practice Center program; David Atkins, MD, MPH, Chief Medical Officer of the AHRQ Center for Practice and Technology Assessment; and Jean Slutsky, PA, MSPH, Task Order Officer for the USPSTF project. The investigators deeply appreciate the considerable support and contributions of members of the RTI International staff: Sonya Sutton, BSPH, for substantive and editorial work, and Loraine Monroe, for superior secretarial assistance. In addition, we are indebted to staff from the University of North Carolina at Chapel Hill and the Cecil G. Sheps Center for Health Services Research: Carol Krasnov for administrative assistance and coordination, and Timothy S. Carey, MD, MPH, Director of the Sheps Center and Co-Director of the RTI-UNC Evidence-based Practice Center.

We also owe our thanks to the following external peer reviewers, who provided constructive feedback and insightful suggestions for improvement of this systematic evidence review: Hillary R. Bogner, MD, Department of Family Practice and Community Medicine, University of Pennsylvania, Philadelphia, Pa.; Gregory Brown, PhD, Department of Psychiatry, University of Pennsylvania, Philadelphia, Pa.; Joseph J. Gallo, MD, MPH, Department of Family Practice and Community Medicine, University of Pennsylvania, Philadelphia, Pa.; Ann P. Haas, PhD, Research Director, American Foundation for Suicide Prevention, Camden, Me.; Charles E. Irwin, Jr., MD, Director, Division of Adolescent Medicine, University of California, San Francisco, San Francisco, Calif.; Douglas Jacobs, MD, American Psychiatric Association, Wellesley Hills, Mass.; Paul A. Nutting, MD, MSPH, Director of Research, Center for Research Strategies, Denver, Colo.; and Harriet MacMillan, Canadian Task Force on Preventive Health Care, London, Ontario, Canada.