# References

1 U.S. Preventive Services Task Force. Guide to Clinical Preventive Services. 2nd ed. Washington, DC: Office of Disease Prevention and Health Promotion; 1996.
2 Strauss GM. Bronchiogenic carcinoma. In: Textbook of pulmonary diseases, 6th ed. Philadelphia, PA: Lippincott-Raven Publishers; 1998.
3 Zang EA, Wynder EL. Differences in lung cancer risk between men and women: examination of the evidence. J Natl Cancer Inst. 1996;88(34):183-92. [pmid: 8632492].
4 American Cancer Society. Cancer Facts and Figures 2003. Available at: http://www.cancer.org/downloads/STT/CAFF2003PWSecured.pdf. Accessed March 11, 2004.
5 Strauss GM. Screening for lung cancer: An evidence-based synthesis. Surg Oncol Clin NAm 1999;8(4):747–74, viii.
6 Osann KE. Lung cancer in women: the importance of smoking, family history of cancer, and medical history of respiratory disease. Cancer Res. 1991;51(18):4893-7. [pmid: 1654203].
7 Tockman MS, Anthonisen NR, Wright EC, Donithan MG. Airways obstruction and the risk for lung cancer. Ann Intern Med. 1987;106(4):512-8. [pmid: 3826952].
8 Hole DJ, Watt GC, Davey-Smith G, Hart CL, Gillis CR, Hawthorne VM. Impaired lung function and mortality risk in men and women: findings from the Renfrew and Paisley prospective population study [see comments]. BMJ. 1996;313(7059):711-5. discussion 715–6. [pmid: 8819439]. [pmcid: 2352103].
9 Skillrud DM, Offord KP, Miller RD. Higher risk of lung cancer in chronic obstructive pulmonary disease: a prospective, matched, controlled study. Ann Intern Med. 1986;105(4):503-7. [pmid: 3752756].
10 Nesbitt JC, Lee JL, Komaki R, Roth JA. Cancer of the lung. In: Holland JF, Bast RC, Jr., Morton DL, Frei E, III, Kufe DW, Weichselbaum RR, editors. Cancer Medicine. Baltimore: William & Wilkins; 1997.
11 Trichopoulos D, Mollo F, Tomatis L, Agapitos E, Delsedime L, Zavitsanos X, et al. Active and passive smoking and pathological indicators of lung cancer risk in an autopsy study. JAMA. 1992;268(13):1697-701. [pmid: 1527879].
12 Fontham ET, Correa P, Reynolds P, Wu-Williams A, Buffler PA, Greenberg RS, et al. Environmental tobacco smoke and lung cancer in nonsmoking women. A multicenter study [published erratum appears in JAMA 1994 Nov 23–30;272(20):1578]. JAMA. 1994;271(22):1752-9. [pmid: 8196118].
13 Davila DG, Williams DE. The etiology of lung cancer. Mayo Clin Proc. 1993;68(2):170-82. [pmid: 8423698].
14 Osann KE, Anton-Culver H, Kurosaki T, Taylor T. Sex differences in lung-cancer risk associated with cigarette smoking. Int J Cancer. 1993;54(1):44-8. [pmid: 8386708].
15 McDuffie HH, Klaassen DJ, Dosman JA. Men, women and primary lung cancer—a Saskatchewan personal interview study. J Clin Epidemiol. 1991;44(6):537-44. [pmid: 2037858].
16 Morbidity and Mortality Weekly Report. Cigarette smoking among adults—United States, 1999. MMWR. 2001;50(40):869-873. [pmid: 11666113].
17 Tonnesen P, Norregaard J, Simonsen K, Sawe U. A double-blind trial of a 16-hour transdermal nicotine patch in smoking cessation. N Engl J Med. 1991;325(5):311-5. [pmid: 2057036].
18 Hurt RD, Sachs DP, Glover ED, Offord KP, Johnston JA, Dale LC, et al. A comparison of sustained-release bupropion and placebo for smoking cessation. N Engl J Med. 1997;337(17):1195-202. [pmid: 9337378].
19 Jorenby DE, Leischow SJ, Nides MA, Rennard SI, Johnston JA, Hughes AR, et al. A controlled trial of sustained-release bupropion, a nicotine patch, or both for smoking cessation.[comment]. N Engl J Med. 1999;340(9):685-91. [pmid: 10053177].
20 Burns DM. Primary prevention, smoking, and smoking cessation: implications for future trends in lung cancer prevention. Cancer. 2000;89(11 Suppl):2506-9. [pmid: 11147637].
21 Halpern MT, Khan ZM, Young TL, Battista C. Economic model of sustained-release bupropion hydrochloride in health plan and work site smoking-cessation programs. Am J Health Syst Pharm. 2000;57(15):1421-9. [pmid: 10938982].
22 Halpern MT, Gillespie BW, Warner KE. Patterns of absolute risk of lung cancer mortality in former smokers. J Natl Cancer Inst. 1993;85(6):457-64. [pmid: 8445673].
23 Tong L, Spitz MR, Fueger JJ, Amos CA. Lung carcinoma in former smokers. Cancer. 1996;78(5):1004-10. [pmid: 8780538].
24 Jett JR. Current treatment of unresectable lung cancer. Mayo Clin Proc. 1993;68(6):603-11. [pmid: 8388526].
25 American Cancer Society. Cancer facts and figures 2000. 2000;Available
26 Mountain CF. Revisions in the International System for Staging Lung Cancer. Chest. 1997;111(6):1710-7. [pmid: 9187198].
27 Cole P, Morrison AS. Basic issues in population screening for cancer. J Natl Cancer Inst. 1980;64(5):1263-72. [pmid: 6767876].
28 Melamed MR, Flehinger BJ, Zaman MB, Heelan RT, Perchick WA, Martini N. Screening for early lung cancer. Results of the Memorial Sloan-Kettering study in New York. Chest. 1984;86(1):44-53. [pmid: 6734291].
29 Fontana RS, Sanderson DR, Taylor WF, Woolner LB, Miller WE, Muhm JR, et al. Early lung cancer detection: results of the initial (prevalence) radiologic and cytologic screening in the Mayo Clinic study. Am Rev Respir Dis. 1984;130(4):561-5. [pmid: 6091507].
30 Garland LH. The rate of growth and natural duration of primary bronchial cancer. Am J Roentgenol Rad Ther Nuc Med. 1966;96(3):604-11.
31 Geddes DM. The natural history of lung cancer: a review based on rates of tumour growth. British Journal of Diseases of the Chest. 1979;73(1):1-17. [pmid: 435370].
32 Soda H, Oka M, Tomita H, Nagashima S, Soda M, Kohno S. Length and lead time biases in radiologic screening for lung cancer. Respiration. 1999;66(6):511-7. [pmid: 10575336].
33 Flehinger BJ, Kimmel M. The natural history of lung cancer in a periodically screened population. Biometrics. 1987;43(1):127-44. [pmid: 3567302].
34 Flehinger BJ, Kimmel M, Melamed MR. The effect of surgical treatment on survival from early lung cancer. Implications for screening. Chest. 1992;101(4):1013-8. [pmid: 1313349].
35 Sobue T, Suzuki T, Matsuda M, Kuroishi T, Ikeda S, Naruke T. Survival for clinical stage I lung cancer not surgically treated. Comparison between screen-detected and symptom-detected cases. The Japanese Lung Cancer Screening Research Group. Cancer. 1992;69(3):685-92. [pmid: 1730119].
36 Fang D, Zhang D, Huang G, Zhang R, Wang L. Results of surgical resection of patients with primary lung cancer: a retrospective analysis of 1,905 cases. Ann Thorac Surg. 2001;72(4):1155-9. [pmid: 11603429].
37 Snijder RJ, Brutel de la Riviere A, Elbers HJ, van den Bosch JM. Survival in resected stage I lung cancer with residual tumor at the bronchial resection margin. Ann Thorac Surg. 1998;65(1):212-6. [pmid: 9456120].
38 Yoshino I, Baba H, Fukuyama S, Kameyama T, Shikada Y, Tomiyasu M, et al. A time trend of profile and surgical results in 1123 patients with non-small cell lung cancer. Surgery. 2002;131(1 Suppl):S242-8. [pmid: 11821819].
39 Greenwald HP, Polissar NL, Borgatta EF, McCorkle R, Goodman G. Social factors, treatment, and survival in early-stage non-small cell lung cancer. Am J Public Health. 1998;88(11):1681-4. [pmid: 9807536]. [pmcid: 1508564].
40 Keller SM, Adak S, Wagner H, Johnson DH. Mediastinal lymph node dissection improves survival in patients with stages II and IIIa non-small cell lung cancer. Ann Thorac Surg. 2000;70(2):358-65. discussion 365–6. [pmid: 10969645].
41 Manser RL, Irving LB, Stone C, Byrnes G, Abramson M, Campbell D. Screening for lung cancer (Cochrane Review). 2002.
42 Harris RP, Helfand M, Woolf SH, Lohr KN, Mulrow CD, Teutsch SM, et al. Methods of the third U.S. Preventive Services Task Force. Am J Prev Med. 2001;20(3S):21-35. [pmid: 11306229].
43 Kubik A, Polak J. Lung cancer detection. Results of a randomized prospective study in Czechoslovakia. Cancer. 1986;57(12):2427-37. [pmid: 3697941].
44 Frost JK, Ball WC Jr, Levin ML, Tockman MS, Baker RR, Carter D, et al. Early lung cancer detection: results of the initial (prevalence) radiologic and cytologic screening in the Johns Hopkins study. Am Rev Respir Dis. 1984;130(4):549-54. [pmid: 6091505].
45 Brett GZ. The value of lung cancer detection by six-monthly chest radiographs. Thorax. 1968;23(4):414-20. [pmid: 5664703]. [pmcid: 471810].
46 Brett GZ. Earlier diagnosis and survival in lung cancer. Br Med J. 1969;4(678):260-2. [pmid: 5345935]. [pmcid: 1629689].
47 Weiss W, Boucot KR, Cooper DA. The Philadelphia pulmonary neoplasm research project. Survival factors in bronchogenic carcinoma. JAMA. 1971;216(13):2119-23. [pmid: 5108675].
48 Weiss W, Boucot KR. The Philadelphia Pulmonary Neoplasm Research Project. Early roentgenographic appearance of bronchogenic carcinoma. Arch Intern Med. 1974;134(2):306-11. [pmid: 4843198].
49 An evaluation of radiologic and cytologic screening for the early detection of lung cancer: a cooperative pilot study of the American Cancer Society and the VeteransAdministration. Cancer Res. 1966;26(10):2083–2121.
50 Hayata Y, Funatsu H, Kato H, Saito Y, Sawamura K, Furose K. Results of lung cancer screening programs in Japan. Recent Results Cancer Res. 1982;82:163-73. [pmid: 7111839].
51 Nash FA, Morgan JM, Tomkins JG. South London Lung Cancer Study. Br Med J. 1968;2(607):715-21. [pmid: 5690439]. [pmcid: 1991645].
52 Ebeling K, Nischan P. Screening for lung cancer - results from a case-control study. Int J Cancer. 1987;40(2):141-144. [pmid: 3610384].
53 Sobue T. A case-control study for evaluating lung cancer screening in Japan. Cancer. 2000;89(11 Suppl):2392-6. [pmid: 11147617].
54 Okamoto N, Suzuki T, Hasegawa H, Gotoh T, Hagiwara S, Sekimoto M, et al. Evaluation of a clinic-based screening program for lung cancer with a case-control design in Kanagawa, Japan. Lung Cancer. 1999;25(2):77-85. [pmid: 10470841].
55 Sagawa M, Tsubono Y, Saito Y, Sato M, Tsuji I, Takahashi S, et al. A case-control study for evaluating the efficacy of mass screening program for lung cancer in Miyagi Prefecture, Japan. Cancer. 2001;92(3):588-94. [pmid: 11505403].
56 Tsukada H, Kurita Y, Yokoyama A, Wakai S, Nakayama T, Sagawa M, et al. An evaluation of screening for lung cancer in Niigata Prefecture, Japan: a population-based case-control study. Br J Cancer. 2001;85(9):1326-31. [pmid: 11720469].
57 Nishii K, Ueoka H, Kiura K, Kodani T, Tabata M, Shibayama T, et al. A case-control study of lung cancer screening in Okayama Prefecture, Japan. Lung Cancer. 2001;34(3):325-32. [pmid: 11714529].
58 Wilde J. A 10 year follow-up of semiannual screening for early detection of lung cancer in the Erfurt country, GDR. Eur Respir J. 1989;2:656-62. [pmid: 2776873].
59 Dales LG, Friedman GD, Collen MF. Evaluating periodic multiphasic health checkups: a controlled trial. J Chron Dis. 1979;32(5):385-404. [pmid: 109452].
60 Friedman GD, Collen MF, Fireman BH. Multiphasic Health Checkup Evaluation: a 16-year follow-up. J Chron Dis. 1986;39(6):453-63. [pmid: 3711252].
61 Sone S, Takashima S, Li F, Yang Z, Honda T, Maruyama Y, et al. Mass screening for lung cancer with mobile spiral computed tomography scanner. Lancet. 1998;351(9111):1242-5. [pmid: 9643744].
62 Kaneko M, Eguchi K, Ohmatsu H, Kakinuma R, Naruke T, Suemasu K, et al. Peripheral lung cancer: screening and detection with low-dose spiral CT versus radiography. Radiology. 1996;201(3):798-802. [pmid: 8939234].
63 Omatsu H, Kakinuma R, Kaneko M, Moriyama N, Kusumoto M, Eguchi K. Successful lung cancer screening with low-dose helical CT in addition to chest x-ray and sputum cytology: the comparison of two screening periods with or without helical CT [abstract 182]. Radiology. 2000;217(Suppl):242.
64 Diederich S, Lenzen H. Radiation exposure associated with imaging of the chest: comparison of different radiographic and computed tomography techniques. Cancer. 2000;89(11 Suppl):2457-60. [pmid: 11147626].
65 Henschke CI, McCauley DI, Yankelevitz DF, Naidich DP, McGuinness G, Miettinen OS, et al. Early Lung Cancer Action Project: overall design and findings from baseline screening. Lancet. 1999;354(9173):99-105. [pmid: 10408484].
66 Swensen SJ, Jett JR, Sloan JA, Midthun DE, Hartman TE, Sykes AM, et al. Screening for lung cancer with low-dose spiral computed tomography. Am J Respir Crit Care Med. 2002;165(4):508-13. [pmid: 11850344].
67 Nawa T, Nakagawa T, Kusano S, Kawasaki Y, Sugawara Y, Nakata H. Lung cancer screening using low-dose spiral CT: results of baseline and 1-year follow-up studies. Chest. 2002;122(1):15-20. [pmid: 12114333].
68 Sone S, Li F, Yang ZG, Honda T, Maruyama Y, Takashima S, et al. Results of three-year mass screening programme for lung cancer using mobile low-dose spiral computed tomography scanner. Br J Cancer. 2001;84(1):25-32. [pmid: 11139308].
69 Jett JR. Spiral computed tomography screening for lung cancer is ready for prime time. Am J Respir Crit Care Med. 2001;163(4):812. discussion 814–5. [pmid: 11282745].
70 Berlin NI, Buncher CR, Fontana RS, Frost JK, Melamed MR. The National Cancer Institute Cooperative Early Lung Cancer Detection Program. Results of the initial screen (prevalence). Early lung cancer detection: Introduction. Am Rev Respir Dis. 1984;130(4):545-9. [pmid: 6548343].
71 Flehinger BJ, Melamed MR, Zaman MB, Heelan RT, Perchick WB, Martini N. Early lung cancer detection: results of the initial (prevalence) radiologic and cytologic screening in the Memorial Sloan-Kettering study. Am Rev Respir Dis. 1984;130(4):555-60. [pmid: 6091506].
72 Martini N. Results of the Memorial Sloan-Kettering study in screening for early lung cancer. Chest. 1986;89(4 Suppl):S325.
73 Fontana RS, Sanderson DR, Woolner LB, Taylor WF, Miller WE, Muhm JR, et al. Screening for lung cancer. A critique of the Mayo Lung Project. Cancer. 1991;67(4 Suppl):1155-64. [pmid: 1991274].
74 Flehinger BJ, Kimmel M, Polyak T, Melamed MR. Screening for lung cancer. The Mayo Lung Project revisited. Cancer. 1993;72(5):1573-80. [pmid: 8394199].
75 Fontana RS, Sanderson DR, Woolner LB, Taylor WF, Miller WE, Muhm JR. Lung cancer screening: the Mayo program. J Occup Med. 1986;28(8):746-50. [pmid: 3528436].
76 Kubik A, Parkin DM, Khlat M, Erban J, Polak J, Adamec M. Lack of benefit from semi-annual screening for cancer of the lung: follow-up report of a randomized controlled trial on a population of high-risk males in Czechoslovakia. Int J Cancer. 1990;45(1):26-33. [pmid: 2404878].
77 Heelan RT, Flehinger BJ, Melamed MR, Zaman MB, Perchick WB, Caravelli JF, et al. Non-small-cell lung cancer: results of the New York screening program. Radiology. 1984;151(2):289-93. [pmid: 6324279].
78 Melamed M, Flehinger B, Miller D, Osborne R, Zaman M, McGinnis C, et al. Preliminary report of the lung cancer detection program in New York. Cancer. 1977;39(2):369-82. [pmid: 837325].
79 Melamed MR. Lung cancer screening results in the National Cancer Institute New York study. Cancer. 2000;89(11 Suppl):2356-62. [pmid: 11147612].
80 Stitik FP, Tockman MS. Radiographic screening in the early detection of lung cancer. Radiol Clin North Am. 1978;16(3):347-66. [pmid: 746141].
81 Baker RR, Tockman MS, Marsh BR, Stitik FP, Ball WC Jr, Eggleston JC, et al. Screening for bronchogenic carcinoma: the surgical experience. J Thorac Cardiovasc Surg. 1979;78(6):876-82. [pmid: 502570].
82 Levin ML, Tockman MS, Frost JK, Ball WC Jr. Lung cancer mortality in males screened by chest X-ray and cytologic sputum examination: a preliminary report. Recent Results Cancer Res. 1982;82:138-46. [pmid: 7111836].
83 Tockman M. Survival and mortality from lung cancer in a screened population: the Johns Hopkins study. Chest. 1986;89(sup):325s-26s. [pmid: 3948543].
84 Woolner LB, Fontana RS, Sanderson DR, Miller WE, Muhm JR, Taylor WF, et al. Mayo Lung Project: evaluation of lung cancer screening through December 1979. Mayo Clin Proc. 1981;56(9):544-55. [pmid: 6267386].
85 Taylor WF, Fontana RS, Uhlenhopp MA, Davis CS. Some results of screening for early lung cancer. Cancer. 1981;47:1114-1120. [pmid: 6263442].
86 Taylor WF, Fontana RS. Biometric design of the Mayo Lung project for early detection and localization of bronchogenic carcinoma. Cancer. 1972;30(5):1344-7. [pmid: 5083070].
87 Sanderson D, Fontana R. Results of Mayo lung project: an interim report. Recent Results Cancer Res. 1982;82:179-86. [pmid: 6287546].
88 Marcus PM, Bergstralh EJ, Fagerstrom RM, Williams DE, Fontana R, Taylor WF, et al. Lung cancer mortality in the Mayo Lung Project: impact of extended follow-up. J Natl Cancer Inst. 2000;92(16):1308-16. [pmid: 10944552].
89 Marcus PM, Prorok PC. Reanalysis of the Mayo Lung Project data: the impact of confounding and effect modification. J Med Screen. 1999;6(1):47-9. [pmid: 10321372].
90 Muhm JR, Miller WE, Fontana RS, Sanderson DR, Uhlenhopp MA. Lung cancer detected during a screening program using four-month chest radiographs. Radiology. 1983;148(3):609-15. [pmid: 6308709].
91 Fontana TR, Sanderson DR, Woolner LB, Miller WE, Bernatz PE, Payne WS, et al. The Mayo Lung Project for early detection and localization of bronchogenic carcinoma: a status report. Chest. 1975;67(5):511-22. [pmid: 1126186].
92 Marcus PM. Lung cancer screening: an update. J Clin Oncol. 2001;19(18 Suppl):83S-86S. [pmid: 11560979].
93 Davis FG, Boice JD Jr, Kelsey JL, Monson RR. Cancer mortality after multiple fluoroscopic examinations of the chest. J Natl Cancer Inst. 1987;78(4):645-52. [pmid: 3104647].
94 Strauss GM, Gleason RE, Sugarbaker DJ. Screening for lung cancer. Another look; a different view. Chest. 1997;111(3):754-68. [pmid: 9118717].
95 McFarlane MJ, Feinstein AR, Wells CK. Clinical features of lung cancers discovered as a postmortem “surprise”. Chest. 1986;90(4):520-3. [pmid: 3757562].
96 Kubik AK, Parkin DM, Zatloukal P. Czech study on lung cancer screening: post-trial follow-up of lung cancer deaths up to year 15 since enrolment. Cancer. 2000;89(11):2363-68. [pmid: 11147613].
97 Henschke CI, Yankelevitz DF, Libby DM, McCauley D, Pasmantier MW, Altorki NK, et al. Early lung cancer action project: annual screening using single-slice helical CT. Ann N Y Acad Sci. 2001;952:124-34. [pmid: 11795431].
98 Harrison's principles of internal medicine. 14th ed. New York: McGraw-Hill; 1998.
99 Sobue T, Moriyama N, Kaneko M, Kusumoto M, et al. Screening for lung cancer with low-dose helical computer tomography: anti-lung cancer association project. J Clin Oncol. 2002;20(4):911-20. [pmid: 11844811].
100 Swensen SJ, Jett JR, Hartman TE, Midthun DE, Sloan JA, Sykes AM, et al. Lung Cancer Screening with CT: Mayo Clinic Experience. Radiology. 2003;226:756-761. [pmid: 12601181].
101 Diederich S, Wormanns D, Semik M, Thomas M, Lenzen H, Roos N, et al. Screening for early lung cancer with low-dose spiral CT: prevalence in 817 asymptomatic smokers. Radiology. 2002;222(3):773-81. [pmid: 11867800].
102 American Cancer Society. Cancer Facts and Figures 2003. Available at: http://www.cancer.org/downloads/STT/CAFF2003PWSecured.pdf. Accessed March 11, 2004.
103 Cotran RS, Kumar V, Robbins SL, Schoen FJ. Robbins Pathologic Basis of Disease. 5th ed. Philadelphia: W.B. Saunders; 1994.
104 Weiss NS, McKnight B, Stevens NG. Approaches to the analysis of case-control studies of the efficacy of screening for cancer. Am J Epidemiol. 1992;135(7):817-23. [pmid: 1595681].
105 Weiss NS. Application of the case-control method in the evaluation of screening. Epidemiol Rev. 1994;16(1):102-8. [pmid: 7925719].
106 Newcomb PA, Norfleet RG, Storer BE, Surawicz TS, Marcus PM. Screening sigmoidoscopy and colorectal cancer mortality. J Natl Cancer Inst. 1992;84(20):1572-1575. [pmid: 1404450].
107 Selby JV, Friedman GD, Quesenberry CP, Weiss NS. A case control study of screening sigmoidoscopy and mortality from colorectal cancer. N Engl J Med. 1992;326(10):653-657. [pmid: 1736103].
108 Moss SM. Case-control studies of screening. Int J Epidemiol. 1991;20(1):1-6. [pmid: 2066205].
109 Schmuecking MW, Baum RP, Leonhardi J, Pichta K, Bonnet R, Presselt N. Evaluation of solitary pulmonary nodules: diagnostic accuracy of F-18 FDG PET in clinical routine [abstract]. Radiology. 2000;217(Suppl):469.
110 Ostroff JS, Buckshee N, Mancuso CA, Yankelevitz DF, Henschke CI. Smoking cessation following CT screening for early detection of lung cancer. Prev Med. 2001;33(6):613-21. [pmid: 11716658].
111 Pigula FA, Keenan RJ, Ferson PF, Landreneau RJ. Unsuspected lung cancer found in work-up for lung reduction operation. Ann Thorac Surg. 1996;61(1):174-6. [pmid: 8561548].
112 Dammas S, Patz EF Jr, Goodman PC. Identification of small lung nodules at autopsy: implications for lung cancer screening and overdiagnosis bias. Lung Cancer. 2001;33(1):11-6. [pmid: 11429191].
113 Black WC. Unexpected Observations on Tumor Size and Survival in Stage IA Non-small Cell Lung Cancer [editoral]. Chest. 2000;117(6):1532-1534. [pmid: 10858376].
114 Lindgren A. Autopsy and cause of death in randomized mammography studies. Qual Assur Health Care. 1993;5(4):303-7. [pmid: 8018887].
115 Austin JH, Romney BM, Goldsmith LS. Missed bronchogenic carcinoma: radiographic findings in 27 patients with a potentially resectable lesion evident in retrospect. Radiology. 1992;182(1):115-22. [pmid: 1727272].
116 Quekel LG, Kessels AG, Goei R, van Engelshoven JM. Miss rate of lung cancer on the chest radiograph in clinical practice. Chest. 1999;115(3):720-4. [pmid: 10084482].
117 Bernard A, Bouchot O, Hagry O, Favre JP. Risk analysis and long-term survival in patients undergoing resection of T4 lung cancer. Eur J Cardiothorac Surg. 2001;20(2):344-9. [pmid: 11463555].
118 Vaporciyan AA, Merriman KW, Ece F, Roth JA, Smythe WR, Swisher SG, et al. Incidence of major pulmonary morbidity after pneumonectomy: association with timing of smoking cessation. Ann Thorac Surg. 2002;73(2):420-5. discussion 425–6. [pmid: 11845853].
119 Romano PS, Mark DH. Patient and hospital characteristics related to in-hospital mortality after lung cancer resection. Chest. 1992;101(5):1332-7. [pmid: 1582293].
120 Myrdal G, Gustafsson G, Lambe M, Horte LG, Stahle E. Outcome after lung cancer surgery. Eur J Cardiothorac Surg. 2001;20(4):694-9. [pmid: 11574210].
121 Deslauriers J, Ginsberg RJ, Piantadosi S, Fournier B. Prospective assessment of 30-day operative morbidity for surgical resections in lung cancer. Chest. 1994;106(6 Suppl):329S-330S. [pmid: 7988256].
122 Battafarano RJ, Piccirillo JF, Meyers BF, Hsu HS, Guthrie TJ, Cooper JD, et al. Impact of comorbidity on survival after surgical resection in patients with stage I non-small cell lung cancer. J Thorac Cardiovasc Surg. 2002;123(2):280-7. [pmid: 11828287].
123 Bach PB, Cramer LD, Schrag D, Downey RJ, Gelfand SE, Begg CB. The influence of hospital volume on survival after resection for lung cancer. N Engl J Med. 2001;345(3):181-8. [pmid: 11463014].
124 Morbidity and Mortality Weekly Report. Cigarette smoking among adults—United States, 1999. MMWR. 2001;50(40):869-873. [pmid: 11666113].
125 National Lung Screening Trial (NLST). 2002;Available at:clinicaltrials.gov/ct/gui/show/NCT00047385;jsessionid=20DAB829F5C5A123FB490104A003A4BA?order=1
126 Tockman MS, Gupta PK, Myers JD, Frost JK, Baylin SB, Gold EB, et al. Sensitive and specific monoclonal antibody recognition of human lung cancer antigen on preserved sputum cells: a new approach to early lung cancer detection. J Clin Oncol. 1988;6(11):1685-93. [pmid: 2846790].
127 Mao L, Hruban RH, Boyle JO, Tockman M, Sidransky D. Detection of oncogene mutations in sputum precedes diagnosis of lung cancer. Cancer Res. 1994;54(7):1634-7. [pmid: 8137272].
128 Palmisano WA, Divine KK, Saccomanno G, Gilliland FD, Baylin SB, Herman JG, et al. Predicting lung cancer by detecting aberrant promoter methylation in sputum. Cancer Res. 2000;60(21):5954-8. [pmid: 11085511].
129 Tsou JA, Hagen JA, Carpenter CL, Laird-Offringa IA. DNA methylation analysis: a powerful new tool for lung cancer diagnosis. Oncogene. 2002;21(35):5450-61. [pmid: 12154407].
130 Gazdar AF, Minna JD. Molecular detection of early lung cancer [editorial; comment]. J Natl Cancer Inst. 1999;91(4):299-301. [pmid: 10050857].
131 Patz EF, Goodman PC, Bepler G. Screening for lung cancer. N Engl J Med. 2000;343(22):1627-1633. [pmid: 11096172].
132 Fong KM, Sekido Y, Minna JD. Molecular pathogenesis of lung cancer. J Thorac Cardiovasc Surg. 1999;118(6):1136-52. [pmid: 10595998].
133 Tockman MS, Mulshine JL. Sputum screening by quantitative microscopy: a new dawn for detection of lung cancer? [editorial]. Mayo Clin Proc. 1997;72(8):788-90. [pmid: 9276609].
134 Mulshine JL, Tockman MS, Smart CR. Considerations in the development of lung cancer screening tools. J Natl Cancer Inst. 1989;81(12):900-6. [pmid: 2659802].
135 Rizvi N, Hayes DF. A “breathalyser” for lung cancer? [comment]. Lancet. 1999;353(9168):1897-8. [pmid: 10371562].