# Acknowledgments

The authors would like to thank Kathryn Krages, AMLS, MA; Susan Wingenfeld; and Kim Peterson, MS, for their help in preparation of the full evidence report and the manuscript. They also thank Mark Helfand, MD, MPH; William Holden, MD; John McAnulty, MD; and James Reuler, MD, for their helpful reviews of the manuscript. Lastly, the authors thank all of the external reviewers of this systematic evidence review.