# Discussion

The personal and public health importance of lung cancer in the United States and worldwide is enormous, and even a small benefit associated with screening could save many lives. However, the outcomes of screening, as shown in this report, are mixed, with some lower grades of evidence (case-control studies) showing benefit and higher grade evidence (randomized controlled trials) not showing benefit and possibly showing harm. Unfortunately, none of the existing randomized trials answer the question faced by clinicians, which is, should patients be screened for lung cancer at all?

The case-control studies from Japan give some support to chest x-ray screening for lung cancer. The studies were methodologically sound and possibly demonstrate a gradient in screening effectiveness by length of interval of screening prior to diagnosis, suggesting a dose-response benefit. An alternative explanation for this gradient is that it is measuring a gradient of healthy screenee behavior. The studies also provide information about the interval of time in which screening might be effective (< 24 months) and the length of lung cancer's detectable pre-clinical stage. Although case-control studies are not considered the gold standard in evaluating screening efficacy and effectiveness, several authors believe they can be a useful and efficient method of evaluating a screening method.^27,^ ^104,^ ^105^ The adoption of flexible sigmoidoscopy as a recommended screening modality for colon cancer screening has been based largely on data from well-conducted case-control studies.^106,^ ^107^ Unfortunately, it is very difficult to overcome the possibilities of volunteer/healthy screenee bias in case-control studies, even well-conducted ones, that might bias the study toward benefit, since those choosing screening may differ from those not being screened in factors which of themselves influence lung cancer mortality.^108^

Although the LDCT studies indicate earlier stage lung cancer can be detected, drawing conclusions from the uncontrolled CT studies is difficult because of the methodologic biases discussed above that could significantly affect interpretation of the findings. Thus, the implications of the CT studies are uncertain due to lack of controls and mortality data. It is possible, based on the stage distribution of the detected malignancies, that survival may be prolonged and mortality reduced. However, because of lead-time and length bias, survival may be prolonged, but mortality unchanged. Randomized trials of LDCT with mortality as an outcome will be needed to definitively evaluate this issue.

The hope of benefit from lung cancer screening is high, however, the implications of screening, especially in the absence of clear-cut benefit, are also great. Evaluating harm or potential harm associated with screening for lung cancer is difficult. One approach to this issue is to evaluate the outcomes of screening. The best data about outcomes from chest x-ray screening come from the recent CT studies since data from the chest x-rays trials accumulated prior to the use of CT for evaluation of x-ray abnormalities, and many patients underwent thoracotomy or biopsy who currently would not. These data are displayed in Table 7, which shows positive test rates and the diagnostic outcomes associated with chest x-rays in a screening setting. Based on the CT studies, most chest x-ray abnormalities are resolved or found to be false positives when evaluated by CT. In a Japanese study, 1,611 individuals underwent CT and chest x-ray and of 23 positive baseline chest x-rays, 22 individuals underwent high-resolution CT, 8 eventually underwent biopsy, and 3 were diagnosed with lung cancer.^99^ In the ELCAP study, 68 individuals had abnormal chest x-rays at baseline, of which 33 were identified on LDCT and referred for further work-up, from which 7 lung cancers were identified. No patient underwent thoracotomy for diagnosis.^65^

In the CT studies, the false positive rate is the number of patients with low-dose CTs requiring further evaluation or follow-up who do not have cancer. Using this criterion, the false positive rates in the CT studies range from 5 to 50% in prevalence screens and 3–12% in incidence screens, with most abnormalities resolved on high-resolution CT. Among the LDCT studies, 4.8–14.5% of patients undergoing HRCT are referred for biopsy, from which most (63–90%) are diagnosed with cancer. For comparison, in US and European clinical practices, approximately half of patients undergoing surgical biopsy of indeterminate nodules subsequently receive a benign diagnosis.^66^ In some studies, false positive rates associated with CT screening appear to decrease when the screened cohorts are periodically rescreened.^68,^ ^97^ Based on data from 3 studies which reported rates of thoracotomy, among 3,928 patients screened, 2 underwent thoracotomy from which one was diagnosed with cancer and 83 malignancies were diagnosed. In the current practice setting, Positron Emission Tomography (PET) scans are used as a non-invasive means of discriminating between malignant and nonmalignant lesions.^109^ In one study, PET scans had 94% accuracy in identifying malignant and non-malignant lesions.^109^ With PET scans, many patients who might have undergone biopsy or thoracotomy in the past might avoid invasive procedures.

All of the individuals with false positive results experience a period of time potentially associated with high anxiety and concern, and for those pursuing further evaluation, the cost and risk associated with it. If there is no benefit to having a false positive screening exam, then many suffer so that few may gain. If benefit can come from being a false positive, then this also needs to be considered. In addition to risk (physical and emotional), there also is the added expense of evaluating the false positive exams, which is significant. Although the false positive rate is high in the lung cancer screening studies, the meaning of a false positive lung cancer screening study (either chest x-ray or CT) to a patient may be different than for other types of false positive cancer screening tests, as the patients potentially have some control over their subsequent risk and may be able to more effectively modify their high-risk behavior. Data from the ELCAP study suggest that CT scan results in combination with smoking cessation counseling improved smoking cessation rates among all participants.^65^ In addition, the ELCAP data show that an abnormal CT finding is associated with nearly two-fold greater odds of decreased smoking or cessation among current smokers (62% reduced or quit rates among those with positive scans compared with 45% rates among those with negative scans).^110^ It is reasonable to assume that an abnormal screening chest x-ray might also influence smoking behavior. However, it is also possible that these rates are higher because the participants are volunteers and/or have formed relationships with the investigators. It is also possible that individuals seeking screening will be reassured by a negative screen and will continue smoking.

An important issue in lung cancer screening is the question of over-diagnosis (and potential over-treatment). The prevalence of lung cancer in the asymptomatic, older, healthy, high-risk ELCAP population was high (3.1%), suggesting that there is a significant pre-clinical pool of lung cancer in high-risk populations. High prevalence has also been shown among individuals being evaluated for lung reduction surgery.^111^ Supporting over-diagnosis is data from the Mayo Lung Project showing increased rates of early tumors in the intensely screened group compared to the control group, without a change in numbers of advanced tumors or subsequent mortality rates, suggesting diagnosis of a pool of indolent tumors. It can be argued, particularly in conjunction with the increased number of lung cancer cases identified in the intervention group of the Mayo Clinic study that this high prevalence reflects the detection of tumors that would not progress in the patient's lifetime. Arguments against an important role for over-diagnosis in lung cancer are based on autopsy and clinical studies. One autopsy series involving 3,286 necropsies identified unsuspected lung cancer in 0.8% of patients who had died of a multitude of causes, suggesting a low rate of clinically unrecognized lung cancer.^95^ However, autopsy may underestimate rates of lung cancer when compared to CT, since the lungs are not always thinly sectioned with autopsy.^112^ Moreover, whether autopsy data are generalizable to living populations is questionable, particularly given selection biases for autopsy.

In the MLP, Marcus et al^88^ reason that the disparity between the finding of prolonged survival among intervention cases compared to control cases, and no difference in mortality between the 2 groups, largely results from lead-time or length-bias and/or over-diagnosis. To evaluate this, the authors consider survival rates from the time of randomization (eliminating lead-time bias), and an increase in survival rates persists in the absence of a mortality benefit. The implication of this finding is that length bias and over-diagnosis account for the disparate findings. An editorial by Black accompanying the most recent update of the MLP^113^ makes a clear argument for the potential of over-diagnosis in lung cancer screening and the implications of over-diagnosis among an elderly population. Although the higher lung cancer mortality rate among the intervention group in the MLP was not statistically significant, a major concern is that the increase in mortality rates might not be due to chance and may be a consequence of screening, e.g., more individuals undergo evaluation and treatment in the screened group with its attendant risk, resulting in a true increase in mortality. Alternatively, an increase in lung cancer mortality rates among screened individuals may be a consequence of misclassification of cause of death or “sticking-diagnosis bias,” meaning that there is a propensity to label any diagnosed malignancy as the cause of death, regardless of the tumor's clinical course, in the absence of autopsy data.^114^ Whether a strong case for over-diagnosis should be made on the basis of current data is uncertain. However, it is possible that with an increasingly sensitive detection tool, such as LDCT, over-diagnosis may be demonstrated to occur. The issue of over-diagnosis is particularly relevant to the harm associated with lung resection for cancer where there is significant mortality and morbidity associated with treatment. More data are needed to definitively evaluate this issue.

Another potential harm in screening is false negative findings with possible false reassurance. The best estimate of the rate of false negative chest x-rays comes from the CT studies where false negative rates as high as 75% have been shown. Clinical series of chest x-ray suggest retrospective identification of lung cancer ranges from 12–90%.^115,^ ^116^ While CT is considered the gold standard for evaluating nodules, it has also has been shown to have false negative rates (e.g., nodules identified retrospectively).^66^ The clinical implications of false negative exams on CT have not been reported to our knowledge. However, lung cancers missed on chest x-ray have been shown to delay diagnosis and are an important source of malpractice claims.^116^ The potential for false reassurance certainly exists, particularly if screenees believe that they are undergoing a definitive examination.

The rate of complications associated with biopsy is not described in the CT studies. The known potential complications depend on the type of biopsy performed. The morbidity and/or mortality associated with thoracotomy for true positive tests is also difficult to evaluate. Complication rates from studies among symptomatic patients are very likely greater than among asymptomatic individuals in screening programs directed at those judged healthy enough to undergo surgery. Thus, it is most appropriate to evaluate these rates from screening studies if the data are available. Unfortunately they are not. In general, studies from symptomatic patients suggest that the more lung tissue removed the greater the morbidity and mortality. Overall, mortality rates range from 1.3 to 11.6% among several series reviewed, with lower mortality among patients undergoing smaller resections.^36,^ ^117^–^121^ For example, the mortality rate among individuals undergoing lobectomy in one series was 0.6% compared with 5.7% among those undergoing pneumonectomy.^120^ Co-morbidity also affects surgical risks; in one US series the rates of operative mortality for resection of stage one non-small cell lung cancer ranged from 0.7 to 6.8% depending on the level of co-morbidity.^122^ The volume of surgery also has been shown to be associated with operative mortality,^119^ with rates of 3% in high volume centers compared with 6% in low volume centers.^123^ The morbidity reported among several series of thoracotomy ranges between 8.8% and 44%, again dependent on the extent of the resection, the volume of the center and the co-morbidity of the patient.^36,^ ^117,^ ^118,^ ^120,^ ^121,^ ^123^

The current standard of clinical practice in the United States is that most patients are not screened for lung cancer.^124^ Based on evidence from the older studies discussed above, particularly the randomized controlled trials, there are no professional organizations that currently recommend routine lung cancer screening. The second U.S. Preventive Services Task Force did not recommend routine screening of asymptomatic persons for lung cancer with chest x-ray or sputum cytology and gave this a D recommendation, meaning that there is fair evidence to support the recommendation that screening should not be performed.^1^ However, because conclusions about lung cancer screening have been based on limited data and no trials have compared screening with no screening, or screening among women, the issue is being re-evaluated. There is enough uncertainty in the field that in 1992, the National Cancer Institute funded a study to evaluate the usefulness of routine chest x-ray screening for lung cancer in both men and women as part of the large Prostate, Lung, Ovarian, and Colorectal Cancer Study (PLCO). This trial involves over 100,000 men and women aged 55–74 who are randomized to receive either 4 annual anterior-posterior chest x-rays or usual care. Data from this study should be available in 2010. The National Lung Screening Trial (NLST), cosponsored by the American College of Radiology Imaging Network (ACRIN) and the Lung Screening Study, sponsored by the Division of Cancer Prevention at the National Cancer Institute, will evaluate screening CT. Ten screening centers derived from the PLCO centers were involved along with 20 ACRIN sites. In the study, men and women aged 55 to 74, with at least 30-pack years of smoking who were not enrolled in the PLCO, were randomized to either a base-line spiral CT with two annual follow-ups, or a base-line chest x-ray with two annual follow-ups. Early data from this trial suggest that there has been overwhelming interest by the public and because of high enrollment; some evidence may be available by the year 2005 if there is a significant mortality reduction associated with screening. It is notable that there is not a placebo (non-screened) group enrolled in either of these trials.^125^

New technologies may also contribute to the early detection of lung cancer and potentially, screening for lung cancer. Some being investigated include: immunocytochemical analysis of sputum with monoclonal antibodies,^126^ and identification of genetic mutations,^127^ abnormal DNA methylation,^128,^ ^129^ abnormal patterns of immunostaining and other molecular changes.^130^–^133^ There are several other potential targets in sputum, bronchial fluid and expired air that may have a role in early lung cancer detection and are currently being investigated.^134,^ ^135^

In summary, there is 1 fair quality individually randomized study of intense chest x-ray screening showing no benefit, as well as the possibility of over-diagnosis, and one cluster randomized study suggesting possible benefit with reduced morality, which was not statistically significant. There are also non-randomized studies of lung cancer screening with chest x-ray that suggest benefit to the screened populations. In addition, pooled data from a Cochrane analysis suggest there may be benefit associated with sputum cytologic screening. There are important methodological limitations to all of these studies. The studies of LDCT have demonstrated that lung cancer can be diagnosed at a significantly earlier stage than currently occurs in clinical practice. However, whether this finding will translate to a mortality benefit is unclear. Critical information will come from the current randomized controlled trials of screening CT. Given the uncertainty associated with chest x-ray screening, it is unfortunate that there are not unscreened control groups in the Lung Screening Study and the NLST; fortunately, data will be available on chest x-ray screening from the PLCO trial in the next 5–8 years. In the meantime, however, other approaches for evaluation of screening might be considered, such as rigorously conducted case-control studies of chest x-ray and/or screening CT, since the results of randomized controlled trials will take years to complete, and lung cancer deaths continue to be major personal and public health issues world-wide. In addition, it is hopeful that new methods of screening for lung cancer will be developed and refined.^135^ Even a small decrease in lung cancer mortality attributed to screening would save thousands of lives each year.