# Summary

1 Five fair-quality Japanese case-control studies show or suggest benefit with chest x-ray screening among men with smoking exposure and women without direct smoking exposure or of mixed risk. There is a suggestion of a gradient of benefit over time in 3 of these studies. Interpretation of these studies is limited by potential screening biases.
2 Two trials evaluated sputum cytology and although neither showed benefit, a recent Cochrane review pooled the findings and found a suggestion of benefit (RR 0.88; 95% CI, 0.74–1.03), though the finding was not statistically significant.
3 Two individually randomized controlled trials of lung cancer screening in high risk men evaluated the role of screening chest x-ray; however, only 1 is of sufficient quality to evaluate the findings and it showed no benefit of intense chest x-ray screening (every 4–6 months) over intermittent chest x-ray screening. One randomized trial of multiphasic screening among relatively young average risk individuals that included chest x-ray showed no benefit, but was compromised by low power, contamination of the control group, and poor compliance. One cluster randomized trial suggested benefit but was not statistically significant.
4 All lung cancer screening specific randomized trials involved the use of a prevalence screen at the beginning of the study. Consequently, there were no completely unscreened control groups.
5 No randomized controlled trials have evaluated lung cancer screening among women; 4 case-control studies from Japan suggest there may be benefit of screening with chest x-ray.
6 Several recent uncontrolled studies of low dose CT have shown that:
  a LDCT is significantly more sensitive than chest x-ray for identifying lung cancer.
  b LDCT identifies a significantly higher proportion of small (low-stage, resectable) lung cancers than chest x-ray.
  c There are high rates of false positive findings in the LDCT studies, and many patients undergo further studies, as well as invasive procedures, to discriminate benign from malignant disease.
  d While survival is anticipated to be longer among the individuals with smaller tumors, the effectiveness of screening cannot be evaluated in the absence of control groups given the biases associated with screening, particularly lead-time and length bias.