# Methods

Our review focused on the outcomes of screening in populations. We reviewed the MEDLINE and Cochrane databases from their inception through January 2003 using the search terms lung neoplasms, lung cancer, and any screening. The search strategy is detailed in Figure 1. To assure complete ascertainment, we reviewed the bibliographies of reviews, editorials, book chapters and letters discussing lung cancer screening. In addition, a recent Cochrane review and analysis^41^ was reviewed for studies that might have been missed. We sought studies evaluating screening in the general population, as well as in high-risk populations, and included observational studies and clinical trials. Observational studies with control groups and randomized trials evaluating disease specific mortality were evaluated for quality according to criteria created by the current USPSTF^42^ (Table 1). To rate each of these studies, we reviewed all related articles describing the studies but did not query study authors. We also used studies of the various screening modalities to estimate the screening test characteristics of chest x-ray (CXR) and low dose CT. Finally, we used data from the screening studies when available, as well as clinical series, to evaluate some of the harms associated with screening and subsequent treatment.

Table 1 U.S. Preventive Services Task Force Quality Rating Criteria

[underlined: Randomized Controlled Trials]
Criteria:; - Initial assembly of comparable groups: adequate randomization, including first concealment and whether potential confounders were distributed equally among groups.; - Maintenance of comparable groups (includes attrition, cross-overs, adherence, contamination).; - Levels of follow-up: differential loss between groups; overall loss to follow-up.; - Measurements: equal, reliable, and valid, and including masking of outcome assessment.; - Clear definition of interventions.; - Important outcomes considered.; - Analysis: Intention-to-treat analysis
Definition of ratings based on above criteria:; - Good: Meets all criteria: comparable groups are assembled initially and maintained throughout the study; follow-up at least 80 percent; reliable and valid measurement instruments applied equally to the groups; interventions clearly defined; important outcomes are considered; and appropriate attention to confounders in analysis. In addition, for RCTs, intention-to-treat analysis is used.; - Fair: Generally comparable groups assembled initially but some question remains whether some (although not major) differences occurred in follow-up; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention-to-treat analysis is done for RCTS.; - Poor: Groups assembled initially are not close to being comparable or maintained throughout the study; measurement instruments are unreliable or invalid or not applied at all equally among groups; outcome assessment not masked; and key confounders are given little or no attention. For RCTs, no intention-to-treat analysis.
[underlined: Case-Control Studies]
Criteria:; - Accurate ascertainment of cases.; - Nonbiased selection of cases and controls with exclusion criteria applied equally to both.; - Response rate.; - Diagnostic testing procedures applied equally to each group.; - Measurement of exposure accurate and applied equally to each group.; - Appropriate attention to potential confounding variables.
Definition of ratings based on above criteria:; - Good: Appropriate ascertainment of cases and nonbiased selection of case and control participants; exclusion criteria applied equally to cases and controls; response rate equal to or greater than 80 percent; diagnostic procedures and measurements accurate and applied equally to cases and controls; and appropriate attention to confounding variables.; - Fair: Appropriate ascertainment of cases and controls and exclusion criteria applied equally to cases and controls, and without major apparent selection or diagnostic work-up bias; response rate less than 80 percent; or attention to some but not all important confounding variables.; - Poor: Major selection or diagnostic work-up biases; response rates less than 50 percent; or inattention to confounding variables.

Figure 1. Search strategy for lung cancer screening