# Introduction

Screening for lung cancer is not currently recommended by any major medical professional organization. The United States Preventive Services Task Force (USPSTF) gave lung cancer screening a “D” recommendation in both 1985 and 1996, meaning that there is fair-quality data to recommend against screening for lung cancer.^1^ This recommendation was largely based on three negative United States trials conducted in the 1970s, 1 evaluating chest x-ray and 2 evaluating sputum cytologic screening. However, since the last Task Force review, several new studies of lung cancer screening have been reported, and greater attention has been directed toward the limitations of existing literature. This review examines studies of lung cancer screening to aid the current US Preventive Services Task Force in updating their recommendation.