# More detailed reviews of recent SERs/meta-analyses

Previous reviews provide an important context for an evidence review. We summarize the results of reviews conducted since 1995, including distinctions from the evidence summary presented in this report.

Kahan, et. al 1995, ^1^ reviewed the results of RCTs on how brief physician interventions with problem drinkers (those who drink at a hazardous level, have developed resulting social or physical problems, and do not exhibit clinical features of serious alcohol dependence) in a health care facility affects self-reported alcohol consumption, serum measures (i.e., GGT), and other measures such as health care utilization and work productivity (sick days, hospital days, absenteeism), and/or other morbidity proxies. Trials involving alcohol treatment clinics or interventions solely by non-physicians were excluded. Eleven studies met inclusion criteria. ^2^ – ^12^ The 4 with the highest validity scores ^7^ – ^9,^ ^12^ were all in primary care settings and showed decreases in weekly alcohol consumption (5–20 standard drinks/week) and more achievement moderate drinking levels (7–19%) for men in active intervention vs. control. The results for women were mixed, with one study reporting decreases ^7^ and the other two not. ^9,^ ^12^ However, adequate power was a concern in one study. ^13^ Most of the 11 studies did not include patients lost to followup in their analyses. One study ^73^ of the six ^10,^ ^65,^ ^73,^ ^102,^ ^109,^ ^127^ measuring utilization/productivity/morbidity outcomes reported statistically signficant reductions in hospital days and absenteeism in the intervention group compared with controls; however, this result may have been due to better medical care in the intervention group; no drinking outcomes were reported in this study. Of the eleven studies reviewed, six were excluded from our review due to non-primary care setting, ^3^ a solely comorbid population focus, ^4^ or poor quality. ^2,^ ^5,^ ^6,^ ^10^

Wilk et al., 1997 ^14^ conducted a meta-analysis of RCTs testing brief (less than one hour) alcohol interventions in heavy drinkers (or those with alcohol abuse or dependence). Twelve studies met inclusion criteria and were included in the final review. ^2,^ ^4^ – ^9,^ ^12,^ ^15^ – ^18^ All except 3 ^15,^ ^16,^ ^18^ were also reviewed by Kahan. Five of the 6 highest-quality trials ^2,^ ^7^ – ^9,^ ^18^ were conducted in the primary care setting and had a summary odds ratio for reduced or moderated drinking among heavy drinkers receiving brief intervention of 1.91 (95% C.I., 1.61–2.27). In these trials, 43.8% of the intervention group achieved alcohol moderation compared to 27.9% of controls. Significant differences in the benefits of brief alcohol intervention were not seen by gender subgroups, number of intervention sessions, or setting (outpatient vs. inpatient), probably because of the small number of trials. Three ^4,^ ^15,^ ^16^ of the 12 studies in this review were excluded from our review because of a non-primary care setting ^15,^ ^16^ or exclusive focus on morbid patients. ^4^ Three were eliminated as poor quality (DRAMS, Persson and magnusson, Kristenson). Of note, the primary-care studies in this review were primarily conducted outside the United States.

Poikolainen (1999) ^19^ conducted a meta-analysis of 7 randomized controlled trials to examine the effectiveness of very brief (5–20 minutes) versus extended brief (up to several visits) physician interventions on average alcohol intake or serum GGT changes in problem drinkers (excluding alcoholics) from primary care populations. In addition to examining intervention intensity, this analysis sought to distinguish itself from earlier meta-analyses by including only studies with random allocation to treatment condition, by not pooling diverse drinking outcomes, and by not pooling results from primary care and hospital-based interventions. The studies in this analysis were primarily a subset of the studies examined by Wilk ^2,^ ^7^ – ^9,^ ^17,^ ^18^ with the addition of one US study ^20^ published in the interim. Studies were allowed to contribute more than one intervention arm or to contribute men and women separately. Thus, 7 studies contributed 14 different comparison datasets, and only 2 studies ^2,^ ^18^ contributed half of the comparison groups (4 and 3 respectively). Outcome levels were calculated by subtracting the control group's results from the intervention group's at followup, regardless of baseline levels. Outcomes were analyzed by intervention intensity (brief vs. extended brief) for women and men separately. Three groups of comparisons (for very brief interventions in men & women and extended brief interventions in women) were statistically homogeneous, but only extended brief interventions in women showed a statistically significant decrease in alcohol intake (-51 grams/week or ½ drink/day); of note, this result was based on data from two studies. Across studies, results tended to favor the intervention group. One ^18^ of the 7 studies reported non-statistically significant greater consumption in the intervention groups compared with controls; this study did not have random assignment of patients (rather, appointment weeks were randomized in blocks). The remainder reported statistically nonsignficant ^9^ or significant reductions in average alcohol intake in intervention patients compared with controls at 6–12 months followup.

Dinh-Zarr et al. published a systematic review of interventions for preventing injuries in problem drinkers (those with alcohol dependence, alcohol abuse, and hazardous use of alcohol) for the Cochrane Injuries Group in the Cochrane Database of Systematic Reviews (DARE) in 1999, ^21^ which was updated in 2000. ^22^ Eighteen studies met the 4 selection criteria: 1) problem drinkers (participants diagnosed with alcohol dependence, alcohol abuse, or hazardous use of alcohol); 2) interventions designed to reduce or eliminate alcohol consumption, prevent hazardous use, or prevent injuries or their antecedents; 3) injury, injury deaths, or their antecedents (falls, motor vehicle crashes, suicide attempts); 4) randomized control trials only. Of these, 11 ^3,^ ^23^ – ^32^ addressed populations not included in our review (e.g., DUI offenders, alcoholics, mentally ill alcoholics, alcohol-abusing workers), 4 ^33^ – ^36^ were in noncomparable settings (e.g., outpatient day or mental health treatment, inpatient units), one ^37^ addressed spouses of heavy drinkers, but was limited to 3-months followup, and 2 ^8,^ ^38^ met inclusion for our review. Of these, neither had data for injury outcomes available for consideration. Thus, this review has little to add to our consideration of interventions for risky/harmful alcohol users in primary care settings.

Moyer et al. (2002) ^39^ completed a meta-analysis of 54 studies that compared brief (4 or fewer sessions) interventions for alcohol use disorders with control conditions or more extensive treatment. The reviewers distinguished between 2 categories of brief interventions: 1) brief interventions designed for those not seeking treatment who are identified by “opportunitistic” screening in settings they are visiting for other reasons (such interventions are typically shorter, less structured, and delivered by a nonspecialist to less motivated patients with less severe alcohol-related problems); and 2) brief interventions for individuals who are help-seeking, persuaded, or mandated to seek alcohol treatment (such interventions are usually longer, more structured and theory-driven, and usually delivered by a specialist). Moyer and colleagues identified 34 studies that fit into the first category of brief intervention potentially relevant to our review. Of these, 11 met inclusion criteria for our review (including one study ^38^ that summarized 8 studies cited separately in Moyer), 9 were omitted because of poor quality or non-comparability to our study population or outcome assessment, and 7 were omitted as outside the primary care setting. There was no consideration of quality in the study inclusion or analyses, although effect sizes were calculated with correction for small sample size bias. Effect sizes were examined for the subset of studies with adequate power (0.80 probability) to detect a medium effect to eliminate bias due to unpublished negative small studies (the “file drawer” problem). Outcomes were assessed 2 ways: 1) using outcomes related to alcohol consumption (quantity-based or time-based); 2) aggregating all drinking-related outcomes for any given study. For studies with multiple brief intervention groups, one comparison (selecting the briefest) was allowed. Among studies with follow up of >6–12 months, the average effect size for the composite of all drinking-related outcomes was .241 (95% C.I., .184, .299); the effect size for alcohol consumption was .263 (95% C.I. .203,.323), but the results for this outcome were statistically heterogeneous. Examining differences in whether studies included or excluded more alcohol-dependent patients did not explain the heterogeneity in consumption outcomes at >6–12 months, although it did explain the heterogeneity in the same outcome at <3 months followup. Aggregate effect size calculations among adequately powered studies (25/34) were similar for both alcohol outcomes to those calculated for the entire 34 studies. Three studies for women and eight studies for men provided effect size information by gender with no significant variation attributable to gender. Little is known about intervention effects beyond one year, since very few (5/34) studies had followup greater than a year.

## Reference List

1 Kahan M, Wilson L, Becker L. Effectiveness of physician-based interventions with problem drinkers: a review. Cmaj. 1995;152(6):851-9. [pmid: 7697578].
2 Heather N, Campion PD, Neville RG, Maccabe D. Evaluation of a controlled drinking minimal intervention for problem drinkers in general practice (the DRAMS scheme). J R Coll Gen Pract. 1987;37(301):358-363. [pmid: 3448228].
3 Kuchipudi V, Hobein K, Flickinger A, Iber FL. Failure of a 2-hour motivational intervention to alter recurrent drinking behavior in alcoholics with gastrointestinal disease. Journal of Studies on Alcohol. 1990;51:356-360. [pmid: 2359309].
4 Maheswaran R, Beevers M, Beevers DG. Effectiveness of advice to reduce alcohol consumption in hypertensive patients. Hypertension. 1992;19:79-84. [pmid: 1346121].
5 Persson J, Magnusson PH. Early intervention in patients with excessive consumption of alcohol: a controlled study. Alcohol. 1989;6(5):403-408. [pmid: 2573364].
6 Kristenson H, Ohlin H, Hulten-Nosslin MB, Trell E, Hood B. Identification and intervention of heavy drinking in middle-aged men: results and follow-up of 24–60 months of long-term study with randomized controls. Alcohol Clin Exp Res. 1983;7(2):203-209. [pmid: 6135365].
7 Wallace P, Cutler S, Haines A. Randomised controlled trial of general practitioner intervention in patients with excessive alcohol consumption. Bmj. 1988;297(6649):663-668. [pmid: 3052668].
8 Anderson P, Scott E. The effect of general practitioners' advice to heavy drinking men. Br J Addict. 1992;87(6):891-900. [pmid: 1525531].
9 Scott E and Anderson. Randomized controlled trial of general practitioner intervention in women with excessive alcohol consumption. Drug Alcohol Rev 1990; 10:313–321.
10 Romelsjo A, Andersson L, Barrner H, Borg S, Granstrand C, Hultman O, et al. A randomized study of secondary prevention of early stage problem drinkers in primary health care. Br J Addict. 1989;84(11):1319-1327. [pmid: 2597808].
11 Nilssen O. The Tromso Study: identification of and a controlled intervention on a population of early-stage risk drinkers. Preventive Medicine. 1991;20:518-528. [pmid: 1678518].
12 Programme on substance abuse: Project on identification and management of alcohol-related problems. Report on phase ii: a randomized clinical trial of brief interventions in primary health care. Babor TF, Grant M, editors. 1–266. 1992. World Health Organization.
13 Scott E and Anderson. Randomized controlled trial of general practitioner intervention in women with excessive alcohol consumption. Drug Alcohol Rev 1990; 10:313–321.
14 Wilk AI, Jensen NM, Havighurst TC. Meta-analysis of randomized control trials addressing brief interventions in heavy alcohol drinkers. Journal of General Internal Medicine. 1997;12(5):274-83. [pmid: 9159696].
15 Antti-Poika I, Karaharju E, Roine R, Salaspuro M. Intervention of heavy drinking—a prospective and controlled study of 438 consecutive injured male patients. Alcohol Alcohol. 1988;23(2):115-121. [pmid: 3390235].
16 Chick J, Lloyd G, Crombie E. Counselling problem drinkers in medical wards: a controlled study. Br Med J (Clin Res Ed). 1985;290(6473):965-967.
17 Nilssen O. The Tromso Study: identification of and a controlled intervention on a population of early-stage risk drinkers. Preventive Medicine. 1991;20:518-528. [pmid: 1678518].
18 Richmond R, Heather N, Wodak A, Kehoe L, et al. Controlled evaluation of a general practice-based brief intervention for excessive drinking. Addiction. 1995;90(1):119-132. [pmid: 7888970].
19 Poikolainen K. Effectiveness of brief interventions to reduce alcohol intake in primary health care populations: A meta-analysis. Preventive Medicine: an International Devoted to Practice & Theory. 1999; 28(5).
20 Fleming MF, Barry KL, Manwell LB, Johnson K, et al. Brief physician advice for problem alcohol drinkers: A randomized controlled trial in community-based primary care practices. Jama: Journal of the American Medical Association. 1997;277(13):1039-1045.
21 Dinh-Zarr T, DiGuiseppi C, Heitman E, Roberts I. Preventing injuries through interventions for problem drinking: A systematic review of randomized controlled trials. Alcohol & Alcoholism. 1999;34(4):609-621. [pmid: 10456590].
22 Dinh-Zarr T, DiGuiseppi C, Heitman E, Roberts I. Interventions for preventing injuries in problem drinkers. Cochrane Database Syst Rev 2000;(2):CD001857.
23 Brown RA. Conventional education and controlled drinking education courses with convicted drunk drivers. Behavior Therapy. 1980;11:632-642.
24 Fitzgerald JL, Mulford HA. An experimental test of telephone aftercare contacts with alcoholics. J Stud Alcohol. 1985;46(5):418-424. [pmid: 2999514].
25 Gallant DM, Bishop MP, Camp E, Tisdale C. A six-month controlled evaluation of metronidazole (Flagyl) in chronic alcoholic patients. Curr Ther Res Clin Exp. 1968;10(2):82-87. [pmid: 4967730].
26 Landrum J, Miles S, Neff R, et al. Mississippi DUI Follow-up Project. Final report. DOT-HS-806 274. 1981. Washington, D.C., National Highway Traffic Safety Administration.
27 Mann RE, Anglin L, Wilkins K, Vingilis ER, et al. Rehabilitation for convicted drinking drivers (second offenders): Effects on mortality. Journal of Studies on Alcohol. 1994; 55(3) May 1994:US, rci.
28 Ojehagen A, Berglund M, Appel CP. Long-term outpatient treatment in alcoholics with previous suicidal behavior. Suicide Life Threat Behav. 1993;23(4):320-328. [pmid: 8310466].
29 Reis RE, Davis LA. First interim analysis of first offender treatment effectiveness. HS-805 577. 1982. Washington, D.C., National Highway Traffic Safety Administration.
30 Reis RE. Analysis of traffic safety impact of educational counseling programs for multiple offense drunk drivers 1980 annual report. HS-806 555. 1982. Washington, D.C., National Highway Traffic Safety Administration.
31 Toteva S, Milanov I. The use of body acupuncture for treatment of alcohol dependence withdrawal syndrome: a controlled study. American Journal of Acupuncture. 1996;24:19-25.
32 Walsh DC, Hingson RW, Merrigan DM, Levenson SM, Cupples LA, Heeren T, et al. A randomized trial of treatment options for alcohol-abusing workers [see comments]. N Engl J Med. 1991;325(11):775-782. [pmid: 1870651].
33 Potamianos G, North WR, Meade TW, Townsend J, Peters TJ. Randomised trial of community-based centre versus conventional hospital management in treatment of alcoholism. Lancet. 1986;2(8510):797-799. [pmid: 2876244].
34 Sitharthan T, Kavanagh DJ, Sayer G. Moderating drinking by correspondence: An evaluation of a new method of intervention. Addiction. 1996;91(3):345-355. [pmid: 8867198].
35 Sitharthan T, Sitharthan G, Hough MJ, Kavanagh DJ. Cue exposure in moderation drinking: A comparison with cognitive-behavior therapy. Journal of Consulting & Clinical Psychology. 1997; 65(5).
36 McCrady BS, Moreau J, Paolino TJ Jr, Longabaugh R. Joint hospitalization and couples therapy for alcoholism; a four-year follow-up. J Stud Alcohol. 1982;43(11):1244-1250. [pmid: 7182681].
37 Barber JG, Crisp BR. The “pressures to change” approach to working with the partners of heavy drinkers. Addiction. 1995;90(2):269-276. [pmid: 7703820].
38 WHO Brief Intervention Study Group. A cross-national trial of brief interventions with heavy drinkers. Am J Public Health. 1996;86(7):948-955. [pmid: 8669518].
39 Moyer A, Finney JW, Swearingen CE, Vergun P. Brief interventions for alcohol problems: a meta-analytic review of controlled investigations in treatment-seeking and non-treatment- seeking populations. Addiction. 2002;97(3):279-292. [pmid: 11964101].