# Screening Instruments

## AUDIT

Circle the number that comes closest to your alcohol use in the PAST YEAR

1 How often do you have a drink containing alcohol?
  0 NEVER
  1 MONTHLY OR LESS
  2 TWO TO FOUR TIMES A MONTH
  3 TWO TO THREE TIMES A WEEK
  4 FOUR OR MORE TIMES A WEEK
2 How many drinks containing alcohol do you have on a typical day when you are drinking?
  0 1 OR 2
  1 3 or 4
  2 5 OR 6
  3 7 TO 9
  4 10 OR MORE
3 How often do you have six or more drinks on one occasion?
  0 NEVER
  1 LESS THAN MONTHLY
  2 MONTHLY
  3 WEEKLY
  4 DAILY OR ALMOST DAILY
4 How often during the last year have you found that you were not able to stop drinking once you had started?
  0 NEVER
  1 LESS THAN MONTHLY
  2 MONTHLY
  3 WEEKLY
  4 DAILY OR ALMOST DAILY
5 How often during the last year have you failed to do what was normally expected from you because of drinking?
  0 NEVER
  1 LESS THAN MONTHLY
  2 MONTHLY
  3 WEEKLY
  4 DAILY OR ALMOST DAILY
6 How often during the last year have you needed a first drink in the morning to get yourself going after a heavy drinking session?
  0 NEVER
  1 LESS THAN MONTHLY
  2 MONTHLY
  3 WEEKLY
  4 DAILY OR ALMOST DAILY
7 How often during the last year have you had a feeling of guilt or remorse after drinking?
  0 NEVER
  1 LESS THAN MONTHLY
  2 MONTHLY
  3 WEEKLY
  4 DAILY OR ALMOST DAILY
8 How often during the last year have you been unable to remember what happened the night before because you have been drinking?
  0 NEVER
  1 LESS THAN MONTHLY
  2 MONTHLY
  3 WEEKLY
  4 DAILY OR ALMOST DAILY
9 Have you or someone else been injured as a result of your drinking?
  0 NO
  1 YES, BUT NOT IN THE LAST YEAR
  2 YES, DURING THE LAST YEAR
10 Has a relative or friend or a doctor or other health worker been concerned about your drinking or suggested you cut down?
  0 NO
  1 YES, BUT NOT IN THE LAST YEAR
  2 YES, DURING THE LAST YEAR

Scoring: 8 or more considered a positive screen for hazardous or harmful drinking.

## CAGE

1 Have you ever felt you should Cut down on your drinking?
2 Have people Annoyed you by criticizing your drinking?
3 Have you ever felt bad or Guilty about your drinking?
4 Have you ever had a drink first thing in the morning to steady your nerves or to get rid of a hangover (Eye opener)?

Scoring: 2 or more positive responses are considered a positive screen for problem drinking.

## T-ACE

1 How many drinks does it take to make you feel high (TOLERANCE)?
2 Have people ANNOYED you by criticizing your drinking?
3 Have you felt you should CUT DOWN on your drinking?
4 Have you ever had a drink first thing in the morning to steady your nerves or to get rid of a hangover (Eye opener)?

Scoring: Positive response to the tolerance item (positive is considered more than 2 drinks) is scored 2 points, other items 1 point each. Total of 2 or more indicates risk drinking.

## TWEAK

1 How many drinks can you hold? (Tolerance)
2 Does your spouse [or do your parents] ever Worry or complain about your drinking?
3 Have you ever had a drink first thing in the morning to steady your nerves or to get rid of a hangover (Eye opener)?
4 Have you ever awakened the morning after some drinking the night before and found that you could not remember a part of the evening before? (Amnesia)
5 Have you ever felt you ought to cut [Kut] down on your drinking?

Scoring: Positive responses to the tolerance (positive is considered more than 5 drinks) and worry items score 2 points each, the other items score 1 point each. Total of 3 or more considered positive for heavy/problem drinking.

## MAST-G

1. | After drinking have you ever noticed an increase in your heart rate or beating in your chest? | YES | NO
2. | When talking with others, do you ever underestimate how much you actually drink? | YES | NO
3. | Does alcohol make you sleepy so often that you often fall asleep in your chair? | YES | NO
4. | After a few drinks, have you sometimes not eaten or been able to skip a meal because you didn't' feel hungry? | YES | NO
5. | Does having a few drinks help decrease your shakiness or tremors? | YES | NO
6. | Does alcohol sometimes make it hard for you to remember parts of the day or night? | YES | NO
7. | Do you have rules for yourself that you won't drink before a certain time of the day? | YES | NO
8. | Have you lost interest in hobbies or activities you used to enjoy? | YES | NO
9. | When you wake up in the morning, do you ever have trouble remembering part of the night before? | YES | NO
10. | Does having a drink help you sleep? | YES | NO
11. | Do you hide your alcohol bottles from family members? | YES | NO
12. | After a social gathering, have you ever felt embarrassed because you drank too much? | YES | NO
13. | Have you ever been concerned that drinking might be harmful to your health? | YES | NO
14. | Do you like to end an evening with a nightcap? | YES | NO
15. | Did you find your drinking increased after someone close to you died? | YES | NO
16. | In general, would you prefer to have a few drinks at home rather than go out to social events? | YES | NO
17. | Are you drinking more now than in the past? | YES | NO
18. | Do you usually take a drink to relax or calm your nerves? | YES | NO
19. | Do you drink to take your mind off problems? | YES | NO
20. | Have you ever increased your drinking after experiencing a loss in your life? | YES | NO
21. | Do you sometimes drive when you've had too much to drink? | YES | NO
22. | Has a doctor or nurse ever said they were worried or concerned about your drinking? | YES | NO
23. | Have you ever made rules to manage your drinking? | YES | NO
24. | When you feel lonely, does having a drink help? | YES | NO

Scoring: Five or more “yes” responses are indicative of an alcohol problem.

## HSS

Check the appropriate answer.
1. | IN THE LAST THREE MONTHS, have you been dieting to lose weight? | | | | | | ___YES | ___NO
| IF YES: How many pounds have you managed to lose?
| ___0 | ___1–3 | ___4–7 | ___8 or more
2. | IN THE LAST THREE MONTHS, have you performed physical activity or exercise in your leisure time at least 20 minutes without stopping, enough to make you breathe hard and/or sweat? | | | | | | ___YES | ___NO
| IF YES: On average, how many days per week have you been exercising?
| ___1–2 | ___3–4 | ___5–6 | ___Every day
3. | IN THE LAST THREE MONTHS, have you been smoking cigarettes at all? | | | | | | ___YES | ___NO
| IF YES: On average, how many cigarettes have you been smoking each day?
| ___1–9 | ___10–19 | ___20–29 | ___30 or more
4. | IN THE LAST THREE MONTHS, have you been drinking alcoholic drinks at all (e.g. beer, wine, sherry, vermouth, or hard liquor)?
| | | | | | | ___YES | ___NO
| IF NO, go to question 5.
| IF YES, ANSWER 4a thru 4c.
Check the appropriate answer.
4 a. | On average, how many days per week have you been drinking beer or wine coolers?
| None | ___1–2 | ___3–4 | ___5–6 | ___Every day
| On a day when you have had beer or wine coolers to drink, how many glasses, bottles, or cans have you been drinking?
| ___1–2 | ___3–4 | ___5–8 | ___9–14 | ___15 or more
AND
4 b. | On average, how many days per week have you been drinking wine, sherry or vermouth?
| ___None | ___1–2 | ___3–4 | ___5–6 | ___Every day
| On a day when you have had wine, sherry, or vermouth to drink, how many glasses have you been drinking?
| ___1–2 | ___3–4 | ___5–8 | ___9–14 | ___15 or more
AND
4 c. | On average, how many days per week have you been drinking liquor (gin, vodka, rum, brandy, whisky, etc.)?
| ___None | ___1–2 | ___3–4 | ___5–6 | ___Every day
| On a day when you have had liquor to drink, how many single shots have you been drinking?
| ___1–2 | ___3–4 | ___5–8 | ___9–14 | ___15 or more
5. IN THE LAST THREE MONTHS, have you felt you should:
a. lose some weight | — | No | — | Sometimes | — | Quite Often | — | Very Often
b. cut down or stop smoking | — | No | — | Sometimes | — | Quite Often | — | Very Often
c. cut down or stop drinking | — | No | — | Sometimes | — | Quite Often | — | Very Often
d. do more to keep fit | — | No | — | Sometimes | — | Quite Often | — | Very Often
6. IN THE LAST THREE MONTHS, has anyone annoyed you or got on your nerves by telling you to:
a. change your weight | — | No | — | Sometimes | — | Quite Often | — | Very Often
b. cut down or stop smoking | — | No | — | Sometimes | — | Quite Often | — | Very Often
c. cut down or stop drinking | — | No | — | Sometimes | — | Quite Often | — | Very Often
d. do more to keep fit | — | No | — | Sometimes | — | Quite Often | — | Very Often
7. IN THE LAST THREE MONTHS, have you felt guilty or bad about:
a. your weight | — | No | — | Sometimes | — | Quite Often | — | Very Often
b. how much you smoke | — | No | — | Sometimes | — | Quite Often | — | Very Often
c. how much you drink | — | No | — | Sometimes | — | Quite Often | — | Very Often
d. how unfit you are | — | No | — | Sometimes | — | Quite Often | — | Very Often
8. IN THE LAST THREE MONTHS, have you been waking up want to:
a. exercise to keep fit | — | No | — | Sometimes | — | Quite Often | — | Very Often
b. smoke a cigarette | — | No | — | Sometimes | — | Quite Often | — | Very Often
c. have an alcoholic drink | — | No | — | Sometimes | — | Quite Often | — | Very Often
d. have something to eat | — | No | — | Sometimes | — | Quite Often | — | Very Often
9. Now that you have completed this form, do you think you currently have:
a. a weight problem | — | No | — | Sometimes | — | Quite Often | — | Very Often
b. a smoking problem | — | No | — | Sometimes | — | Quite Often | — | Very Often
c. a drinking problem | — | No | — | Sometimes | — | Quite Often | — | Very Often
d. a fitness problem | — | No | — | Sometimes | — | Quite Often | — | Very Often
10. Thinking back, would you say at any time in the past you had:
a. a weight problem | — | No | — | Sometimes | — | Quite Often | — | Very Often
b. a smoking problem | — | No | — | Sometimes | — | Quite Often | — | Very Often
c. a drinking problem | — | No | — | Sometimes | — | Quite Often | — | Very Often
d. a fitness problem | — | No | — | Sometimes | — | Quite Often | — | Very Often