# Appendix: Tables

Table 1. Definitions of drinking disorders, patterns, and categories.

Table 2. Intensity of intervention definitions.

Table 3. Screening Tool Detail.

Table 4. Screening Instrument Performance for Detecting Risky/Harmful Drinking in Primary Care Samples.

Table 5. Screening Instrument Performance for Detecting Alcohol Abuse or Dependence in Health Care Settings.

Table 6. Literature Search Terms.

Table 7. Evidence Table Glossary.

Table 7 Evidence Table Glossary

Abbreviation | Definition
RCT | Randomized Controlled Trial
HMO | Health Maintenance Organization
DR | A drink as defined by the standard drink definition for the study
IG | Intervention Group (IG1 - indicate different groups)
CG | Control Group
AUDIT | Alcohol Use Disorders Identification Test
CAGE | CAGE (acronym)
(SD) | Mean (Standard Deviation)
(SEM) | Mean (Standard Error of the mean)
F/U | Follow-Up
GGT | Serum Gamma Glutamyl Transpeptidase
PC | Primary Care
NR | Not Reported
M.D. | Medical Doctor
Ph.D. | Doctor of Philosophy
HSQ | Health Screening Questionnaire
Incl Exc Criteria | Inclusion/Exclusion Criteria
cL | Centiliters
# | Number
% | Percentage
n | Number in group or denominator for analysis
N | Total number in study

Table 8. Evidence for Adults.

Table 9. Evidence for Pregnant Women.

Table 10. Excluded Adult Intervention Studies (Includes those excluded for quality and other reasons).

Table 11. Screening and screening-related assessment procedures used in the brief intervention trials included in this review.

Table 12. Studies Awaiting Assessment and Ongoing Studies.

Table 13. Baseline Consumption of Alcohol Among Risky/Harmful Drinkers Recruited for Interventions in Primary Care (Mean DR/week) *.

Table 14. Summary of Results for Adults.