# Recommendations for Future Research

Screening and screening-related assessment. Although several valid and reliable standardized instruments are available for screening for alcohol-related risks and problems in primary care (AUDIT, CAGE, TWEAK, T-ACE), more information is needed about performance of these instruments in subgroups, such as those based on racial/ethnic minority status. Additionally, future research adapting the structure (items) and scoring (cutpoints) of established instruments for important subgroups would be useful. Efforts are continually being made to reduce the time required to complete screening, and several standardized instruments are being evaluated in shorter form, including a 3-question AUDIT ^192^ (and some single-item screens for heavy episodic drinking). ^193^ – ^196^ This is an important area for ongoing research. Appropriate screening tools for adolescents and older adults are not yet firmly established. Future research in these areas is sorely needed. Similarly, more research on practical means to integrate screening and screening-related assessment procedures into real-world primary care settings is necessary.

Brief Interventions. Screening and brief multi-contact behavioral counseling interventions are effective in reducing at-risk alcohol consumption in most populations studied. Little is known, however, about effective strategies for persuading physicians and health plans to adopt these practices as a regular part of routine health care. Future research should work to establish the structures that produce the most cost-effective interventions in real-world settings. These should include determining the best methods to use for screening administration (e.g., in-person interview, paper-and-pencil questionnaire, computer-based questionnaire, computer-based telephone interview) as well as the best and most cost-effective persons or machines to administer screenings.

Fortunately, important work in these areas is currently underway. The Robert Wood Johnson Foundation's Initiative “Cutting Back: Managed Care Screening and Brief Intervention for Risky Drinking” is a multi-center project designed to identify the costs and benefits of primary care screening and brief intervention in managed care settings. Results from the project (which is directed by Thomas F. Babor, PhD, MPH, and John C. Higgins-Biddle, PhD) are expected within the year.

Physicians and health plans also need to know the structure of the most effective and cost-effective interventions, including the minimum length of intervention necessary and the best methods for followup as it appears indicated (e.g., time to first followup, frequency of followup, length of followup period, intensity of the followup intervention). Additionally, further research is needed to address differences in the effectiveness of the types of health care providers or others who might conduct screening and screening-related assessments or interviews (e.g., physicians, nurses, health educators, receptionists) and deliver interventions and followup contacts. Other future research should address the real-world questions of how to integrate risky alcohol use screening and interventions with those for other risky behaviors, and whether it alters the efficacy of alcohol-only interventions.

Several special populations should also be targeted for additional research on best practices for screening and brief intervention. We found only 1 publication that addressed screening and intervention with adolescents and that met our setting-based inclusion criterion (general health care setting). Most work with adolescents and young adults has been completed in communities, schools, or colleges. It is possible that such settings represent the most efficacious ways to access these groups, but primary care visits appear to present an important opportunity to screen and intervene with these at-risk populations. Future research is needed to determine if health care settings present appropriate circumstances for interventions with adolescents and young adults, and to identify the most effective methods for screening and intervention. Similarly, more research is needed to determine the most effective types of interventions for pregnant women, for elderly individuals, and for members of key U.S. minority groups, such as Native Americans, in particular, and non-Whites in general. These groups were underrepresented in the available studies

Health Effects. More research is needed to directly evaluate the impact of primary-care based alcohol interventions on short and long-term health effects. Better measures of non-medical outcomes, including quality of life and reduced life problems, seem appropriate, particularly in shorter-term outcome studies. Harms associated with screening, screening-related assessment, and brief intervention for alcohol use disorders should be specifically addressed in future trials.

## Acknowledgements

The authors appreciate the contributions of Shannon Sanner, MPH, Gary Miranda, MA, Paula Smith, BSN, Elizabeth Haney, MD, and Jae Douglas, PhD to this project. The Cost Working Group of the USPSTF (Somnath Saha, MD, MPH, Thomas J. Hoerger, PhD, Jeanne S. Mandelblatt, MD, MPH, Steven M. Teutsch, MD, MPH, Albert L Siu, MD, MHP, and Mark Helfand, MD, MS) were involved in a separate analysis of economic studies related to brief primary-care based alcohol interventions to reduce risky/harmful alcohol use, and a summary of their findings is reported here.