# Discussion

## Adults

Table 14 of the Appendix summarizes our results across all key questions for interventions in adults. Findings are discussed for each key question separately below.

Table 14 Summary of Results for Adults

Key Question | Strength of Evidence | Consistency of Evidence | Comment
Key Question 1: Is there direct evidence that behavioral counseling interventions to reduce risky or harmful alcohol use reduce morbidity and/or mortality? | Fair—3 fair-to-good quality brief, brief multi-contact, and more intensive multi-contact intervention trials provided long-term results. | Results are mixed. After 4 years, brief multi-contact counseling intervention non-significantly reduced mortality in men and women. After 3–21 years, more intensive multi-contact intervention significantly reduced all-cause mortality in younger men and alcohol-related causes of death in middle-aged men and men of all ages. After 10 years, brief single-contact counseling intervention had no effect on morbidity/mortality measures. | No long-term effects for low intensity interventions and mixed results for more intensive interventions, with effects seen primarily in more intensive intervention with repeated contacts up to five years. Followup longer than 4 years may be needed, and mortality benefits may primarily or only accrue to specific subgroups such as younger men. Publication bias cannot be ruled out—other studies may have examined long-term results but failed to publish them because they weren't favorable to counseling.
| Evidence Grade: I | Overall Evidence: FAIR
Key Question 2: What methods were used to identify target populations for the behavioral counseling interventions? | Fair—Relevant primary care patients were identified for 4 fair- and 7 good-quality RCTs and 1 fair-quality CCT. | Various methods were used that approximate a two-step process (screening and screening-related assessment) to identify patients for intervention. | Research staff administered all screening-related assessment and it isn't clear how this would be done in real-world primary care settings.
| | Screening often included standardized instruments that are feasible to be done in primary care and have been shown to perform adequately in primary care populations. | Screening for intervention is different to separate from screening and assessment procedures related to trial inclusion and to measuring intervention efficacy.
| | Overall Evidence: FAIR
Key Question 3: What are adverse effects associated with alcohol use screening and screening-related assessment? | Poor—intervention studies generally ignored potential adverse effects of assessment. | Overall Evidence: POOR
Key Question 4: Does behavioral counseling intervention in primary care reduce risky or harmful alcohol use in the targeted subgroup? | Good—4 fair- and 7 good-quality RCTs, and 1 fair-quality | [underlined: Brief or very brief single-contact interventions]: Five of 8 of these interventions had no effect on mean alcohol consumption; the three effective interventions were tested in two trials with multiple intervention arms. One primarily tested very brief and brief single-contact interventions, but had optional followup at some centers; the other tested brief single and multiple-contact interventions in the same trial. Four of five showed no improvement in proportion drinking as recommended. [underlined: Brief mulit-contact interventions]: consistent evidence primarily from good-quality studies (5 of 7 interventions measuring average consumption; 5 of 5 interventions measuring proportion achieving recommended limits) supported the hypothesis that these interventions resulted in clinically significant reductions in alcohol use that last at least 1 year. One good-quality US RCT supports maintenance of alcohol behavior changes for up to 48 months in men and women. | More recent US studies contribute to consistent evidence from studies worldwide that screening and interventions integrated into primary care reduce alcohol consumption and improve use patterns.
| CCT of relevant primary care populations. | | All alcohol use measures are self-report.
| Evidence Grade: I | Overall Evidence: GOOD
Key Question 4a: What are the essential elements of efficacious interventions? | Limited—inadequate reporting of intervention detail and too few studies within intensity categories to separate intervention elements from more intensive contact that seems to be needed for effectiveness. | All effective studies report incorporating at least advice, feedback, and goal-setting, while most also include assistance and followup. | Intervention processes and elements used in these trials generally support recommendations from national organizations (NIAAA)
| | Overall Evidence: POOR-TO-FAIR
Key Question 5: Are there other positive outcomes from behavior counseling interventions to reduce risky/harmful alcohol use? | Poor-to-Fair—fewer studies address this question specifically. | Most studies show no effect on problems, psychosocial issues, general health, other lifestyle issues, or on health care utilization. | Generally, null findings may reflect lack of an effect, lack of appropriate measures, and/or reduced power for secondary analyses.
| Evidence Grade: I | Overall Evidence: POOR-TO-FAIR
Key Question 6: What are adverse effects associated with behavioral counseling interventions for risky/harmful alcohol use? | Poor—no studies address this question. | Overall Evidence: POOR
Key Question 7: What healthcare system influences (features of the health care practice team, features of the practice setting, features of he health care system) are present in effective assessments and interventions to reduce risky/harmful alcohol use and/or its outcomes? | Fair—Some intervention RCTs describe training and supports to implement the trial in the clinical setting. | Many studies provided training ranging from .25 to 2.5 hours. All studies supplied patient assessment for the clinical staff, and many also provided critical support functions for the implementation (prompts, summarized assessment results, timely provision of intervention materials). Other health care staff (nurses, health educators) assisted in intervention and/or assessment in some studies. Implicit in the delivery systems were also referral resources for more severely affected/dependent drinkers. | To obtain the results from these studies in real-world clinical practices, implementation will require; 1 a commitment to planning,; 2 allocation of resources to consistently identify at-risk/harmful alcohol-using patients, and; 3 resources to help clinicians deliver services to the range of alcohol-using patients identified.
| | Overall Evidence: FAIR

Key Question 1. Fair overall evidence (KQ1) examines whether behavioral counseling interventions such as those tested above result in reduced morbidity and/or mortality (see Appendix: Table 14). The results of these trials are mixed. One good-quality trial reported a trend toward reduced all-cause mortality in males and females after 4 years in those receiving brief multi-contact intervention compared with controls (3 versus 7 deaths, p>.10). ^108^ In another good-quality followup, after 3–21 years, younger men in the cohorts invited to health screenings and interventions in the Malmo trial had significantly lower total mortality rates (24/10,000 person-years) than non-invited controls (30/10,0000 person-years ) (p<.02); ^109^ cause-specific rates for death from “other causes” (primarily alcohol-related) were significantly lower in middle-aged males with elevated GGT levels randomized to receive the extended intervention (37% vs. 52%) (p<.026) compared with controls in the nested trial within Malmo. ^107^ Similarly, alcohol-related mortality was reduced among younger males and all males (18/10,000 person-years vs. 23/10,0000 person-years) in the invited cohorts compared with the non-invited cohorts. ^109^ However, most of these analyses are for subgroups and the Malmo trial tested quite an extended intervention (at least 18 months and potentially up to 5 years) and selected drinkers based on confirmed GGT elevations; such drinkers may have been more severely affected than those targeted by most behavioral counseling interventions reviewed here. Another study examining 10-year followup from a very brief/brief single-contact intervention ^119^ found no long term effects on alcohol consumption, morbidity, or mortality between intervention and controls. Few of the fair-to-good intervention studies reviewed here included measures such as quality of life, problems, and other non-medical outcomes. Among these limited studies, there were few findings of differences between interventions and controls. One fair study examined the association between drinking reductions and improved quality of life measures among all primary care patients identified for a trial testing both brief single and multi-contact interventions. ^122^ This exploratory analysis suggests that quality of life measures, particularly related to mental health functioning and alcohol-related problems, may improve among those who reduce their drinking by at least 20%–30%, and that such measures may be important in detecting shorter-term health effects.

Key Question 2. Many trials, particularly those more recently conducted, selected drinkers with risky/harmful drinking due to heavy episodic use (bingeing) in addition to recent high average consumption and problems or consequences associated with alcohol use. This reflects a growing awareness of the risk of patterns of heavy episodic use in addition to average consumption. Illustrating this trend toward lower thresholds for risky drinking behavior, the most recent study ^126^ also included those who self-reported recent driving after drinking three or more drinks. The definition associated with “high” for recent average consumption has declined over time, and more recent studies have also tended to exclude most or all drinkers with evidence of dependence or abuse from participation in the brief primary care intervention trial.

Behavioral counseling intervention trials used various methods to identify alcohol users appropriate for brief primary-care based intervention. This patient identification process for trial participation could be roughly considered to include screening (identifying all those potentially eligible patients for alcohol misuse intervention in primary care or elsewhere) and screening-related assessment (qualifying those patients eligible to receive primary care-based intervention and referring on those needing more intensive specialty care). Screening typically involved self-administered questions/questionnaires, such as AUDIT, CAGE, quantity/frequency/per occasion use), with about 11–18% of screened patients having a positive result. Screening-related assessment involved clinical interview and judgment and generally results in a final yield of about 7% of patients appropriate for brief primary care intervention. Screening and screening-related assessment for alcohol misuse was often masked, at least initially, in an overall health risk assessment approach.

This two-step strategy seen in most of the trials approximates that recommended by the NIAAA, in which all patients identified as drinking alcohol are asked about usual quantity and frequency of drinking, about the maximum number of drinks in the past month, followed by the CAGE questions, with follow-up screening-related assessment to assess for specific alcohol problems and possible dependence. ^40^ Patients with documented problems and/or dependence are referred for specialty treatment, while those whose consumption exceeds recommended guidelines, but who don't meet dependent/severe problem criteria, are considered appropriate for brief, primary-care based intervention. The NIAAA screening and screening-related assessment strategy has been validated with regard to alcohol abuse and dependence ^73^ but has not been validated with regard to detecting risky drinkers. A similar approach has recently been recommended by the World Health Organization for use of AUDIT, whereby four levels of intervention intensity are identified as appropriate to 4 ranges of scores. ^71^

The screening approaches used in these trials were reasonably similar to the screening instruments commonly tested for use in primary care populations (CAGE, AUDIT) shown to have reasonable-to-good test performance among primary care populations. Systematic reviews of screening instruments recommend use of structured validated instruments that can alone (AUDIT) or in combination (CAGE plus standardized quantity/frequency questions) detect those with at-risk, harmful, and abuse/dependent drinking. The use of these instruments in conjunction with clinical assessment and judgment seems similar enough to the two-stage patient identification process for the trials reviewed to expect that such an approach would result in similar patients being identified for brief primary care based intervention in real-world settings. However, the overall evidence for this is fair as it is extrapolated from efficacy trials, and includes the important caveat that the screening-related assessment step was necessary, but not tested as part of the clinical protocol in most studies reviewed.

Key Question 3. There is poor evidence to assess harms associated with alcohol use screening or screening-related assessment.

Key Question 4. Good evidence supports brief multi-contact behavioral counseling interventions to reduce alcohol misuse among primary care populations. The majority of trials showing an intervention effect are of good quality, and show net mean reductions in weekly drinks from 2.9–8.7 mean DR/week (13–34% net reduction in drinking). Three of 6 good-quality studies that reduced average consumption also reported reducing the proportion bingeing. Across studies, however, bingeing remained fairly common among intervention participants even after intervention. Given the growing evidence for risks associated with such use, future intervention research should more directly target interventions and outcome measures to address heavy occasional use. In 7 good-quality studies, 10–19% more intervention participants achieved recommended or safe drinking limits than controls. Fair-to-good evidence also supports the lack of an effect of very brief or brief single contact interventions on alcohol consumption measures, although this finding could reflect other issues, such as incomplete intervention delivery. This finding contrasts with the significant results seen for very brief and brief tobacco interventions among adults in primary care and other medical settings. ^183^ The classification scheme we devised to categorize intervention intensity considered together some studies with very extended/intensive intervention ^128^ with others much less intensive (e.g., Curry ^126^ ). Similarly, variations in protocol between different sites ^119^ and a higher intensity design that didn't quite fit the other studies ^122^ made our categorization less than perfect. Nevertheless, our categorization clearly distinguished between those with and without followup contact after the initial intervention, and demonstrated that even interventions that invest greater time in a single contact are unlikely to be successful.

Earlier intervention studies and reviews raised concerns that women either might not be as responsive to brief interventions as men, or might be so responsive to screening alone that brief intervention would not confer much additional benefit. Recent reviews, however, have found no important gender differences in outcomes of brief interventions, ^55,^ ^98^ and our results support this contention. We found no systematic differences between women and men in the effectiveness of adult primary care interventions (see Appendix: Figures 4, 5, 6 & 8) and available data appear to support the benefit of these interventions in older adults. Insufficient data were available to evaluate other adult subgroups, since non-White participation was quite low.

We chose fairly restrictive inclusion criteria to emphasize the internal and external validity of the behavioral counseling interventions reviewed. We limited our review to studies rated “fair” to “good” on the USPSTF-based criteria, with emphasis on particular threats to validity relevant to this body of research. Many alcohol research and intervention studies suffer from high attrition rates that can differ between treatment and controls. ^184^ Although survey respondents and non-respondents probably differ, current evidence does not clearly indicate in which direction—i.e., dropouts are not always heavier drinkers. ^184^ Since drop-outs might represent those more resistant to change who are part of the population of patients clinicians would encounter in daily practice, we distinguished between studies that conducted intent-to-treat analysis to include all participants by replacing all missing values and intent-to-treat analyses that analyzed only complete cases. We also rated as “poor quality” studies with high (above 25%) and/or differential attrition if intent-to-treat analyses with replacement of missing values were not available. As summarized, the body of evidence reported here consistently shows a moderate net benefit at 12 months from brief multi-contact interventions to reduce alcohol misuse among primary care patients. Longer-term followup of patients from one randomized controlled clinical trial ^108,^ ^121^ suggests maintenance of changed alcohol use patterns among intervention participants over 48 months. Studies showing a null effect were primarily of fair quality and generally less intensive in terms of number of contacts, and/or number of intervention elements included in the intervention.

An issue with validity for this type of literature is the use of self-report alcohol consumption for outcomes, since the veracity of self-report has been the subject of recurrent concern. Earlier research tried to rely on “objective” laboratory measures, but found these to be insensitive indicators of problem use or of change. ^185^ Similarly, more “objective” collateral reports may underestimate alcohol use. ^185,^ ^186^ Moreover, carefully conducted alcohol use self-reports have been found to be as accurate or more accurate than other measures when collected under ideal circumstances, such as within a general health assessment by non-clinical personnel outside the clinical setting, and when the patient is not inebriated. ^186^ Given these guidelines, we feel that the self-reported alcohol consumption data that form the basis for this report are reasonably valid. Nothing is known about whether demand characteristics (subjects feeling the need to report what they think the interviewer wants to hear) could have affected the net findings of improved alcohol consumption patterns reported here.

To enhance external validity, we included only studies with health care personnel intervening with a broad range of non-dependent patients from a primary care outpatient setting. Most of the studies involved the person's usual care primary clinician in some way in the intervention, and most were conducted in community-based or other loosely affiliated primary care practices. However, some studies were conducted in practices within research networks or in HMOs with associated research institutions. The studies that occurred in non-research affiliated primary care also tended to be the least intensive, which somewhat confounds considerations of external generalizability. However, 2 lower-intensity randomized controlled intervention trials ^124,^ ^126^ had some level of research affiliation but little evidence of effect, lending more credence to the lack of intensity interpretation. We also evaluated conditions associated with the research (such as whether research or clinical personnel conducted portions of the screening/screening-related assessment/intervention, need for training and systems support, and use of incentives) that might affect the feasibility of dissemination to routine practice (see also KQ7). Probably the greatest challenge in applying this literature to routine practice relates to instituting and delivering systematic screening and screening-related assessment procedures for primary care patients. In all studies, this was done primarily or exclusively by research personnel, and research personnel were often responsible for providing additional supportive services (charting, reminding, providing materials) that set up the clinician's participation. It would not be realistic to expect even modest effects from implementing behavioral counseling interventions for alcohol misuse that did not include systems and adequate personnel to provide these critical portions of the process. Generally, studies also tended to exclude more severe alcohol-using, dependent, or problematic drinkers, or to refer them to more intensive specialty treatment outside primary care. Such systems need to be available to provide the full range of alcohol services to those who could present to primary care.

Key Question 4a. Limited evidence hampers the ability to distinguish effective elements of interventions. It is difficult to separate higher-intensity intervention effects from intervention components. We examined five key elements identified in several articles, including the last TF recommendation, of brief interventions in primary care to reduce alcohol misuse. ^40,^ ^55,^ ^64,^ ^105^ All effective interventions included at least feedback, advice, and goal-setting, while most also delivered further assistance and followup. These elements are consistent with the 5A's approach to describing behavioral counseling interventions in clinical care adopted by the USPSTF. ^56^ Each of the 5A's is described briefly below to include these key intervention elements for behavioral counseling interventions to reduce risky/harmful alcohol use.

1 Assess: All studies used screening and screening-related processes that can be delivered a variety of ways: asking about alcohol use to identify current drinkers, and briefly screening current drinkers to determine patterns of use (e.g., average quantity/frequency, per-occasion use; AUDIT) and alcohol-related problems (CAGE; AUDIT). For those who screen positive, more in-depth interview-based screening-related assessment help distinguish those at increased risk for alcohol problems, those currently experiencing mild-moderate problems, and those who have severe problems or are alcohol-dependent. Although studies generally did not describe this process well, algorithms are available ^40,^ ^71,^ ^72^ to guide clinicians and their staff through this process, including identifying more severely affected patients to refer for specialty services. Additionally, guidelines for appropriate responses to patients based on AUDIT scores are now available (see section on Feasible and Accessible Screening Tools for Risky/Harmful Alcohol Use). ^72^
2 Advise: All effective studies included this component. Clinical advice to reduce or stop drinking, as well as advice about guidelines for low-risk drinking, is a consistent element in primary care interventions. Feedback about current drinking patterns, problem indicators (lab test results), or medical consequences is commonly part of this step.
3 Agree: Some studies cited the style or approach of the intervention (e.g., a patient-centered approach) and most included at least goal-setting. This is consistent with use of empathetic, nonconfrontational style to agree upon a plan of action ^40^ with explicit goal-setting, usually for moderation rather than abstinence (depending on problem severity). ^105^
4 Assist: Most effective studies also specified using various approaches and patient choices (menu of options) to provide the information, skills, and supports to the patient to achieve his/her goal. This assistance occurred at the time of the visit and through followup contacts, and often involved offering choices among approaches to behavior change. ^40^ Although not explicitly described, recruitment processes referred many patients whose behavioral counseling or support needs exceeded usual primary care resources. Guides to this process are also available. ^40^
5 Arrange/Adjust: Most effective studies provided more than one contact, allowing followup monitoring for ongoing assistance and support in the incremental process of changing alcohol use behaviors. ^40^ By virtue of the study procedures, patients in both treatment and controls conditions were reminded of their alcohol use through repeated contacts to monitor ongoing patterns of use.

Key Question 5. There is poor-to-fair evidence to evaluate the impact of alcohol behavioral counseling interventions on health care utilization and costs. In some studies, intervention participants reported fewer emergency department visits and hospital days, although most differences were not statistically significant. Generally null findings may reflect lack of an effect or reduced power for secondary analyses. Cost effectiveness studies were limited in number and inconsistent in methods and assumptions. Future research is needed to confirm suggested effects in the direction of cost-savings and/or comparable cost-effectiveness to other preventive interventions.

Key Question 6. There is insufficient evidence to assess harms associated with behavioral counseling interventions for risky/harmful alcohol users in primary care.

Key Question 7. Fair evidence also suggests that, to obtain the results from these studies in real-world clinical practice, implementation will require health systems supports such as: 1) commitment to planning, 2) allocation of resources/staff to consistently identify at-risk/harmful alcohol-using patients, and 3) resources to help clinicians be prepared for (clinician training) and to deliver services (e.g., prompts, materials, reminders, referral resources) to the range of alcohol-using patients identified.

Potential Clinical Significance of Primary Care Interventions for Adults. If effective processes for identifying and intervening among patients with risky/harmful alcohol use were implemented in primary health care settings, the prevalence of alcohol problems would likely be reduced both through early identification (the systematic detection of and effective intervention with risky alcohol users at an asymptomatic or early stage of development) and through case finding (the identification of and intervention with or referral of harmful users who are not currently receiving services within the health care system). ^57^ Given the broad range of diseases, disorders, and social problems that are associated with alcohol misuse, estimating the relevance of a public health approach is more challenging, and clear evidence on the aggregate-level impact of screening and brief intervention programs in primary care is lacking. ^37^

To begin to address this challenge, researchers have made an attempt to model the impact of different early-intervention strategies to reduce consumption on the prevalence of alcohol-related problems and use disorders. These strategies target all drinkers (“population strategy”), or the risky/harmful drinkers (“high-risk strategy”) to modify or stop their alcohol consumption. ^187^ A recent cross-sectional analysis using the 1992 National Longitudinal Alcohol Epidemiologic Survey (NLAES) examined the impact of a 25% reduction in consumption on projected prevalence of alcohol abuse and dependence using a strategy targeting all drinkers compared to one targeting only those with risky/harmful consumption patterns. Both strategies assumed a reduced quantity of alcohol consumed on drinking days among targeted drinkers. US drinkers were equally distributed among 3 categories: those whose daily consumption never exceeds moderate consumption cutpoints, those whose consumption sometimes exceed cutpoints, and those whose consumption usually exceeded cutpoints. To achieve the same residual prevalence of abuse or dependence (13%) would require a 25% reduction in average daily alcohol intake for all current drinkers, a 28% reduction in average daily intakes for all sometimes immoderate drinkers, or a 41% reduction in average daily consumption by usually immoderate drinkers. ^188^ Thus, given current consumption patterns, a 3% reduction in the prevalence of abuse/dependence would require a 25–41% decrease in average daily intake, depending on the population of drinkers targeted.

Applying the results of our review to these estimates, all of the interventions reviewed targeted individuals who at least sometimes drank immoderately. Thus, a 28% reduction in average intake would need to be achieved to reduce the prevalence of abuse/dependence by 3%. Our review showed a net percentage point reduction of 10–25% among most extended brief/extended intervention, with greater effects suggested in older adults and perhaps one subgroup of women. These are a very conservative estimates, however, based on the net reduction in drinking (when both intervention and controls commonly reported reduced consumption after screening, screening-related assessment and followup). Thus, well-implemented, efficacious, extended brief/extended interventions might well achieve an adequate reduction in average intake to meet the goals, particularly considering the fact that a good program of intervention would provide repeated interventions over time to non-responders.

Studies also show that 10 to 18% more of intervention participants achieved recommended or safe alcohol intakes. These guidelines are related to lower short-term and long-term health risks, so that corresponding proportions of individuals would be expected to have some health benefits from such changes if maintained.

Few interventions had an effect on maximum per occasion (binge) consumption measures. A significant residual (25–50%) was still binging at the end of intervention followup across studies. Because of the apparent relationship between bingeing and risk of injury, accidents, and alcohol-related problems, future intervention research should more directly address binge usage and should also aim to include among the intervention population those who are low-average users but with occasional heavy use.

Despite the relative complexity of defining the impact of addressing alcohol-related problems at the individual level, directing interventions at individuals in primary care represents a feasible and potentially very effective component of an overall public health approach to reducing alcohol misuse because of: 1) the prevalence of risky/harmful drinkers among those visiting primary care; 2) the misuse of alcohol being reasonably easily identified and addressed through feasible, relatively low-intensity interventions; 3) the apparent feasibility of integrating brief screening and alcohol services into routine primary care based on the types of studies conducted; and 4) the fact that almost all alcohol-related consequences can be minimized by reducing excess frequency and/or quantity. ^37^

Adult Summary. There is consistent evidence for the effectiveness of brief multi-contact interventions to reduce risky/harmful drinking in primary care settings, at least up to 1 year, or longer in some cases. ^108^ Perhaps as noteworthy is the lack of consistent treatment effects among single contact interventions, with up to 15 minutes of initial contact intensity. Breadth of studies in multiple countries and settings argue for the effectiveness of brief multi-contact interventions across diverse populations; results of our review, in combination with comprehensive meta-analyses reported by Moyer ^99^ and others, make a convincing argument for such interventions as part of the public health approach to this problem. The Community Task Force is currently summarizing other complementary approaches. Although a few studies have examined the potential cost effectiveness of primary-care based strategies to reduce risky/harmful alcohol use, ^179^ – ^181^ data suggesting possible cost-effectiveness or savings need to be bolstered by future more definitive research. The next important step should be determining effective strategies for persuading physicians and health plans to adopt screening and brief intervention as part of routine practice. Current research points the way to persuading physicians to accept screening and intervention materials ^189^ and to providing training that increases screening and intervention activities. ^190,^ ^191^ It seems clear from this review that there is a need for adequate systems support (systematic, perhaps centralized, screening and screening-related assessment by clinical staff, prompting and screening-related assessment and intervention materials provision, ongoing training and support) for busy primary care clinicians to deliver these interventions; this observation is supported by some research. ^191^

## Pregnant Women

The few randomized controlled trials of interventions in prenatal care settings to eliminate or reduce drinking among pregnant women tended to show small or negligible effects. In comparison to the studies of adults summarized above, these trials tended to include much lighter drinkers, to be smaller, and to have much shorter followup periods. Relatively long screening and screening-related assessments as part of the recruitment in two of the trials may have mitigated potential intervention effects. A strength of these studies, however, was their inclusion of larger numbers of minority and poor patients than in the general adult studies. Given the importance of reducing the risk of fetal harm from exposure to alcohol, further research among pregnant women and women considering pregnancy is a high priority.

## Adolescents

Only 1 trial met our criteria for inclusion, and it was aimed at preventing drinking rather than reducing heavy or hazardous drinking. This trial's positive results at 6-month followup among students recruited at sports physicals are promising, and suggest that this subpopulation is also understudied.