# Results

## Key Question 1: Is there direct evidence that behavioral counseling interventions to reduce risky or harmful alcohol use reduce morbidity and/or mortality?

We identified four reports of health outcomes associated with long-term followup of adult interventions. ^107^ – ^110^ Fleming et al. reported outcomes at 48 months among 282 male and 292 female adults drinking more than 14 drinks/week (men) or 11 drinks/week (women). ^108^ Drinkers were randomized as part of a trial in 17 community-based primary care practices to receive either usual care or 2 brief (15-minute) physician intervention visits about one month apart, each followed by 2 brief (5-minute) telephone calls by a nurse. ^111^ The intervention visits used a workbook protocol that focused the interaction on drinking cues, a drinking agreement written as a prescription, and self-monitoring through drinking diary cards. Long-term (48 month) outcomes included self-reported alcohol use, self-reported health care utilization, self-reported accidents and injuries, and legal events and deaths ascertained from state agencies. Compared to the control group, the intervention group maintained statistically significant reductions in drinking outcomes (weekly alcohol use, number of binge episodes) seen at earlier time points. The intervention group self-reported fewer emergency department visits, fewer days in the hospital, and fewer motor vehicle accidents or moving violations, although only self-reported hospital days were statistically significant (429 vs. 664 days, p<.05). Intervention group participants incurred 32% fewer legal arrests (28 vs. 41), but only the subgroup of arrests for controlled substance/liquor violations were significantly different between intervention and control (2 vs. 11, p<0.05). Seven deaths were reported in the control group and 3 in the treatment group at 48-months follow-up (p>0.10).

Berglund ^109^ reported on the long-term follow up of the Malmo Screening and Intervention Study (MSIS), a controlled study that conducted screenings for cardiovascular risk factors and high alcohol intake between 1974-1992. All middle-aged males and females in the community were identified by birth year, and cohorts in alternating birth years were invited to health screenings at the outpatient Department of Preventive Medicine, with about 70% of invited cohorts attending. Nurses performed examinations that involved physical measures, functional tests, risk factor identification, and laboratory tests. Those in the invited group who screened positive for increased serum gamma-glutamyl transpeptidase levels (GGT) and history of excessive alcohol consumption (about 11% of all those screened) were offered repeat MD office visits (1/2 hour) as often as every 3 months over at least 18 months, preceded by repeat lab and consumption measures. MDs gave feedback concerning lab results and consumption measures, advised patients to drink moderately, and encouraged self-monitoring for situations/cues to heavy use. A treatment goal of moderation rather than abstinence was agreed upon. ^112^ Participants were also contacted monthly by an RN during active treatment. Over a 5-year period, active treatment was offered until lab tests and/or consumption normalized, and was then reduced to maintenance (2 MD visits and 2 RN contacts per year). Those in control cohorts received usual care. Subjects in both invited and non-invited cohorts were followed through 1995, beginning at the same age for individuals in both cohorts and using local registers to examine death rates and causes. Although there have been various followup reports over the years for this study, ^109,^ ^113^ – ^115^ earlier reports are not included in the rest of this review by virtue of not collecting intermediate alcohol consumption measures on all participants, by high attrition rates, or by reporting results for subgroups. The 2000 report covers mortality measures on all individuals in both invited and non-invited cohorts, after individual followup periods from 3–21 years that were comparable between intervention and control cohorts. Using intention-to-treat analysis, total and cause-specific mortality rates did not differ between intervention and control groups among men. However, significantly fewer male intervention cohort members (18/10,000 person-years) than male control cohort members (23/10,000 person-years) had “other death mortality” (p<.02). “Other deaths” were those attributable to causes other than ischemic heart disease, stroke, other cardiovascular disease (CVD), total CVD, or cancer. Younger men at baseline (aged 32–37) had both lower total mortality rates (24/10,000 person-years compared to 30/10,000 person-years) (p<.02) and lower “other death” cause-specific mortality rates (p<.03) in intervention versus control cohorts, respectively. Mortality rates did not differ between cohorts for female participants, however the average length of followup was shorter than that for males.

A more recent report from a nested randomized controlled trial within Malmo Screening and Intervention Study ^107^ examined cause-specific mortality rates among a subgroup of men aged 45–49 with elevated serum gamma-glutamyl transferase levels (GGTs) at the initial screening examination who were followed a median of 13 years. Those with 2 elevated GGTs within 3 weeks were randomized to receive the active intervention (as described above) (n=365) versus letter notification and follow up at 2 years (n=302). A second control group was formed from those with a single elevated GGT who did not meet study inclusion criteria (n=311). Deaths were determined from a centralized registry, and a high proportion (88–100%) of deaths were autopsied during the followup time period. Overall death rates were 12.7% (38/365 in IG, 42/302 in CG1, and 44/311 in CG2), and were not reported as differing statistically between groups. Deaths were divided into four discrete causes: 1) alcohol-related deaths (ARD)—including accidents in an alcohol-intoxicated state, cause unknown in known alcoholics, death in known alcoholics with tissue evidence of alcoholic intoxication and no other specific demonstrable cause of death, deaths from organic complications of alcoholism, or suicide/pneumonia in known alcoholics; 2) coronary heart disease (CHD); 3) cancer; and 4) miscellaneous. Alcohol-related death rates were higher (52%) in both control groups than in the intervention group (37%) [risk ratio=2.0 (1.1–3.6), p=.026] and were higher than CHD death rates in control groups. CHD deaths exceeded alcohol-related deaths only in the intervention group. Among those with ARD in all groups, most had received treatment for alcoholism at some point.

Among risky/harmful non-dependent drinkers in the Australian arm of the WHO trial (n=554), 9-month reductions in average drinking consumption and unsafe drinking patterns in intervention vs. control subjects did not result in long-term differences in alcohol consumption (median alcohol consumption, mean reduction in consumption from baseline), in morbidity, problem drinking, or mortality rates, or in diagnoses of abuse/dependence at 10 year follow-up. ^110^ Younger drinkers (mean age 35 years vs. 41.6 years at baseline) were differentially lost to followup. The authors note that there is no evidence that brief advice and counseling without regular followup and reinforcement can sustain long-term reductions in drinking behavior, and therefore any associations with improved health outcomes.

Few fair-to-good quality intervention studies included in this review reported morbidity outcomes such as problem scores, ^116^ – ^119^ psychological scores, ^116,^ ^118^ and other beneficial outcomes, such as improvements in lifestyle, and reduced accidents or injuries ^111,^ ^116,^ ^120,^ ^121^ in the original time frame of the study. In 2 of 4 studies examining problem scores, both groups generally improved over the duration of the trials, but no differences were seen at followup between interventions and controls. ^116,^ ^117^ The other 2 (male and female arms of the same study design) showed no changes from baseline to followup within or between groups. ^118,^ ^119^ The 5 studies ^111,^ ^116,^ ^118,^ ^120,^ ^121^ measuring changes in outcomes such as general health, smoking depression, and accidents or injuries found no changes over the trials or differences between intervention and control groups.

Another adult intervention study ^122^ has reported a post hoc analysis of the association between changes in drinking and quality of life and alcohol-related problems. ^123^ A self-selected, statistically comparable subgroup (213/301) of those randomized to receive either usual care, brief, or extended brief intervention completed quality of life (SF-36, reported as the physical component summary, PCS, and the mental health component summary, MCS) and alcohol-related problem (Short Inventory of Problems, SIP) measures at baseline and 12 months. Since all groups equally improved their drinking from baseline to 12-month followup, all drinkers were combined and stratified by whether or not they had reduced their drinking by 30% or more over that time period. Seventy-seven (36%) of subjects sustained a 30% or more decrease in their drinking; these subjects averaged 85.5 drinks/month (SD 77.3) at baseline and 22.5 drinks/month (SD 29.0) at 12-month followup, while those that didn't decrease 30% or more had steady alcohol intakes of 66.0 (SD 61.2) and 65.3 (SD 59.1) drinks/months at baseline and 12 months respectively. Over 12 months, PCS, MCS, and SIP scores were relatively unchanged in those whose drinking was not reduced by at least 30%; compared to these, drinkers who reduced their average intake by 30% or more showed significantly improved MCS and SIP scores (p<.002) even after removing those with definite abuse/dependence. When the cut points were changed to include those with a 20% or greater reduction of alcohol consumption (n=98), MCS and SIP improvements remained statistically significant. Requiring a 40% or greater reduction of alcohol consumption (n=65) to define “improvers” retained the statistically significant comparative improvement in SIP scores, but eliminated the improvement in MCS scores. PCS scores appeared to improve primarily in those with definite abuse/dependence who reduced their drinking. These findings should be considered preliminary as they are limited by the post hoc nature of the analyses that addressed “responders” regardless of intervention condition and by virtue of including only two-thirds of the original participants who agreed to complete the additional outcome assessments analyzed in this study.

## Key Question 2: What methods were used to identify the target populations for the behavioral counseling interventions?

We examined the recruitment, screening, and study participant identification methods used in the 12 studies included in our main evidence table for adults. Brief descriptions of these methods and procedures, inclusion and exclusion criteria related to alcohol consumption patterns and alcohol problems, and descriptive data on the numbers of participants included or excluded at various study stages are depicted in Table 11 of the Appendix.

Table 11 Screening and screening-related assessment procedures used in the brief intervention trials included in this review

Study | Screening/identification procedures | Drinking pattern inclusion criteria | Drinking pattern exclusion criteria | Recruitment yield(s); enrolled/eligible (%);
Curry, 2002 ^126^ Health Psychology 2003 | Patients with advance primary care appointments with 23 participating physicians in an HMO clinic were contacted by phone after physicians reviewed lists and applied exclusion criteria. Remaining patients were screened for “at-risk drinking patterns” via a 10–15 minute phone interview about general health behaviors that included the AUDIT, modified Cahalan questions about drinking quantity and frequency, and single questions about frequency of binge drinking and driving after drinking. Alcohol use questions were imbedded with other health behavior items to help mask the focus on drinking. | Standard Drink (DR) = 14 g ETOH | 1 AUDIT ≥16 (referred to specialty treatment); 2 known by physician to be alcoholic | 5187 patients identified;
| Eligible patients were randomized prior to their routine appointments; those who kept the appointments were enrolled in the study. | AUDIT ≤15 | | 4793 eligible after MD exclusions;
| | AND | | 3439/4793 completed screening survey;
| | 1 or more of the following drinking patterns: mean ≥ 2 drinks/day in the past month OR ≥ 2 episodes of binge drinking (≥ 5 drinks/occasion) in the past month OR ≥ 1 episode of driving after ≥3 drinks in past month | | 380/3439 screened eligible (11%);
| | | | 307 enrolled / 380 eligible;
| | | | (28 refused to give study information to MD, 19 referred to specialty SA treatment, 26 did not have a primary care visit in study window)
| | | | N=307/3439 (8.9%)
Ockene, 1999 ^127^ Archives of Internal Medicine | 4 primary care internal medicine practices were randomly assigned to intervention or control conditions. Patients of 46 participating clinicians were screened with the Health Habits Survey by phone, mail, or at a primary care visit to identify “high-risk drinking” or 2+ CAGE responses. | Standard drink = 12.8 g ETOH | 1 Current participation in an alcohol intervention program | 1760/9772 screened positive for “high-risk drinking” (18%);
| Patients who screened positive were invited to a 20–35 minute Lifestyle Interview, either in-person or by phone, which included the Time-Line Follow-Back (TLFB) interview to record alcohol consumption over past 7 days. Study-eligible patients were then invited to enroll. Alcohol use questions were imbedded with other health behavior items to help mask the focus on drinking. | “High risk drinkers:” | | 1500/1760 were phoned;
| Patients were enrolled if they made a primary care visit within 6 months of the Lifestyle Interview. | men > 12 DR/week | | 703/1500 remained eligible after assessment interview;
| | OR ≥5 DR/occasion ≥once in past month; | | 545/703 made a primary care visit within study window;
| | women > 9 DR/week | | 530 enrolled / 545 eligible (10 refused and 5 were too ill to participate)
| | OR ≥4 DR/occasion ≥once in past month; | | N=530/9772
| | OR
| | ≥2 positive CAGE questions
Fleming, 1999 ^120^ Journal of Family Practice | Participating physicians were recruited from fee-for-service and HMO primary care clinics. Patients 65 or older attending scheduled appointments were asked to complete a modified Health Screening Survey, and those who screened positive for “problem drinking” were invited to a 30-minute, in-person Researcher Lifestyle Interview, which included the Time-Line Follow-Back (TLFB) interview to record alcohol consumption over past 7 days. Study-eligible patients were then randomized. Alcohol use questions were imbedded with other health behavior items to help mask the focus on drinking. | Standard drink: 12–14 g ETOH | 1 Alcohol treatment or alcohol withdrawal symptoms in previous year;; 2 MD advice to change alcohol use in previous 3 months;; 3 >50 DR/week | 6073/6693 completed screening survey;
| | (study pop. age ≥65) | | 656/6073 screened positive (11%) & were invited to in-person assessment interview;
| | Men >11 drinks (>132 g alcohol)/week; | | 396/656 completed assessment interview;
| | women >8 drinks (>96 g alcohol)/week; | | 180/396 remained eligible
| | OR | | 158 enrolled / 180 eligible by interview (22 excluded by chart audit or refused)
| | ≥2 positive CAGE questions; | | N=158
| | OR
| | Binge drinking (men: ≥4 DR/occasion; women: ≥3 DR/occasion on ≥2 times in last 3 months).
Fleming, 1997 ^111^ Journal of the American Medical Association | 64 participating physicians were recruited from fee-for-service and HMO primary care clinics. Patients attending scheduled appointments were asked to self-administer a Health Screening Survey, and those who screened positive for “problem drinking” were invited to a 30-minute, in-person Research Lifestyle Interview, which included the Time-Line Follow-Back (TLFB) interview to record alcohol consumption over past 7 days. Study-eligible patients were then randomized. Alcohol use questions were imbedded with other health behavior items to help mask the focus on drinking. | Standard Drink = 12 g ETOH | 1 Alcohol treatment or alcohol withdrawal symptoms in previous year;; 2 MD advice to change alcohol use in previous 3 months;; 3 >50 DR/week | 2925/17,695 screened positive (16.5%);
| | Men >14 DR/week; | | 2450/2925 willing to participate in assessment interview;
| | Women >11 DR/week | | 1705/2450 completed assessment interview;
| | OR | | 852/1705 remained eligible
| | ≥2 positive CAGE questions; | | 774 enrolled / 852 eligible by interview (78 excluded by chart audit or refused)
| | OR | | N=774
| | Binge drinking (men: ≥5 DR/occasion; women: ≥4 DR/occasion on ≥4 times in last 30 days).
Manwell, 2000 ^121^ Alcoholism: Clinical and Experimental Research | [This trial examined a subset of 5979 female patients age 18–40 included in Fleming 1997; recruitment methods were identical.] | Standard Drink = 12 g ETOH | 1 Alcohol treatment or alcohol withdrawal symptoms in previous year;; 2 MD advice to change alcohol use in previous 3 months;; 3 >56 DR/week | 730/5979 screened positive for problem drinking (12%);
| 64 participating physicians were recruited from fee-for-service and HMO primary care clinics. Patients attending scheduled appointments were asked to self-administer a Health Screening Survey, and those who screened positive for “problem drinking” were invited to a 30-minute, in-person Research Lifestyle Interview, which included the Time-Line Follow-Back (TLFB) interview to record alcohol consumption over past 7 days. Study-eligible patients were then randomized. Alcohol use questions were imbedded with other health behavior items to help mask the focus on drinking. | (Women only, age 18–40) | | 454/730 completed assessment interview;
| | >11 DR/week | | 205 enrolled / 454 interviewed (249 ineligible after interview)
| | OR | | N=205
| | > 4 DR/occasion
| | OR
| | ≥2 positive on CAGE
Senft, 1997 ^124^ American Journal of Preventive Medicine. | Patients attending primary care visits with 47 clinicians at 3 HMO clinics were asked to self-administer a screening questionnaire, which included the AUDIT instrument, in waiting rooms. Those scoring in the “hazardous drinking range” were asked to enroll, and acceptors were randomized prior to seeing the clinician. | Standard drink approx. 0.5 oz ETOH | 1 AUDIT >21 | 620/8017 screened positive for hazardous drinking (7.7%);
| No attempt was made to shield the study's focus on drinking and health. Recruitment and intervention occurred at a single, routine primary care visit. | AUDIT 8–21 (85% of sample) | | 516 enrolled / 620 eligible (20 refused, 84 were missed)
| | OR | | N=516
| | sum of 2 AUDIT quantity-frequency item scores was ≥5
| | OR
| | ≥6 DR per occasion at least weekly
Anderson & Scott, 1992 ^116^ British Journal of Addiction | 8 group practices participated. Patients self-administered the Health Survey Questionnaire, which was distributed either by mail or at primary care visits. | Standard Drink = 10g ETOH (unit) | 1 Weekly consumption ≥1050g (105 DR);; 2 Received advice during the previous year to cut down on alcohol use | 524/8483 met weekly consumption criterion (6.2%);
| Men meeting the consumption criterion were invited to an in-person assessment interview, which included a one-week drinking diary. Eligible men were randomized after interview. | (Men only) | | 419 invited for assessment interview;
| | Weekly consumption ≥ 350g (35 DR) | | 205/419 completed interview;
| | | | 194/205 met consumption criterion in past week;
| | | | 154 enrolled / 194 interviewed
| | | | (40 met exclusion criterion)
| | | | N=154
Nilssen, 1991 ^125^ Preventive Medicine | All adults within an age range in the city of Tromso were invited to attend a comprehensive health screening exam. At the end of the exam, participants were asked to complete and return by mail a questionnaire that included questions about alcohol consumption. Eligibility was determined by GGT levels and reported alcohol consumption. | Standard Drink NR | 1 Medical records reviewed to exclude persons with alcoholism or hepato-biliary diseases | 21647/27198 screened;
| | Elevated GGT (50–200 U/l men, 45–200 U/l women); | | 776/21647 with GGT in range;
| | AND | | 381/776 eligible by questionnaire;
| | Alcohol drinking at least 2–3 times per week; | | 338 enrolled / 381 surveyed (43 excluded for medical reasons)
| | OR | | N=338
| | Single occasion drinking equivalent to 1 bottle of wine 1–2 times per month.
Wallace, 1988 ^128^ British Medical Journal | 47 group practices participated. Patients self-administered the Health Survey Questionnaire, which was distributed either by mail or at primary care visits. | Standard drink = 1 | 1 Received medical advice about drinking during the previous year; 2 GGT > 150 IU/l | 4454 were deemed eligible for interview (denominator not reported);
| Patients meeting consumption criterion were invited to an in-person “lifestyle and health survey interview,” which included a past-week “systematic history” of alcohol consumption. Eligible patients were randomized after interview. | English unit (NR, but elsewhere=10 g ETOH | | 4203/4454 invited to assessment interview (251 excluded for medical reasons, death, moved away);
| | Men ≥35 units/week; | | 2571/4203 attended assessment interview;
| | Women ≥21 units/week | | 929 eligible based on past week consumption
| | OR | | 909 enrolled/929 eligible (20 met exclusion criteria)
| | Alcohol consumption not exceeding these limits, but ≥2 positive CAGE questions | | N=909
| | OR
| | self-assessed drinking problem
Maisto, 2001 ^122^ Journal of Studies on Alcohol | Patients at 12 primary care clinics self-administered screening questionnaires (a “lifestyle survey”), which included the AUDIT, in waiting rooms. Eligible patients were invited to attend an assessment interview within 2 weeks of the screening visit. | Standard Drink = 0.6 oz ETOH | 1 No drinking in past year; 2 Substance abuse treatment in past year; 3 Acute alcohol withdrawal symptoms | 1388/13273 screened positive at primary care visits (10.5%);
| The AUDIT, additional alcohol quantity-frequency questions, and a last 30-day history of consumption using the TLFB were administered during this in-person interview. Those who remained eligible after interview were invited to enroll. | AUDIT ≥ 8 | | 343/1388 consented to assessment interview
| | OR | | 301 enrolled / 343 assessed (42 met exclusion criteria)
| | Men ≥ 16 DR/week; | | N=301
| | Women ≥ 12 DR/week
WHO Brief Intervention Study Group, 1996 ^119^ American Journal of Public Health | Patients were recruited during visits to a variety of health care settings in 8 nations using an initial screening interview to identify those with alcohol consumption patterns that raised risk of chronic disease or acute alcohol-related problems. | Standard Drink = 1.5 cL ETOH (14g or 0.5 oz) | 1 Prior treatment for liver damage or alcohol dependence; 2 Warning from MD or other health professional to abstain; 3 Past or recent morning drinking; 4 Recent very high consumption (men 120g/day or women 80g/day) | 1559 enrolled / screened & interviewed (number not reported)
| Those selected were administered a 20-minute health interview (baseline assessment), and those who remained eligible were asked to enroll. Alcohol use questions were imbedded with other health behavior items to help mask the focus on drinking. | Men >50 g/day; or > Women 32 g/day; | | N=1559
| | OR
| | ≥6 DR/occasion)
Richmond, 1995 ^117^ Addiction | 119 GPs from 40 group practices participated. Patients were enrolled in a weekly sequential process (non-random assignment to study conditions). Patients attending primary care visits were asked to self-administer a 3-minute Health & Fitness Questionnaire in the waiting room. Eligible patients were asked participate in a research study about lifestyles; consenting patients provided blood samples and were given a 15-minute in-person assessment interview, which included a past-week drinking diary. Those remaining eligible were enrolled. | Standard Drink = 10 g ETOH | 1 Severe alcohol dependence (Ph score > 10); 2 Severe alcohol related problems (MAST > 20); 3 Previous or current alcohol treatment; 4 Any alcohol consumption medically contraindicated | 13017/14725 completed screening questionnaires;
| | Men >35 DR/week; | | 894/13017 met drinking inclusion criteria (6.5%);
| | Women >21 DR/week | | 713/894 invited to enroll in study (181 leaving area or missed at visit);
| | | | 467/713 agreed to participate;
| | | | 378 enrolled / 467 (89 met exclusion criteria or did not attend assessment interview)
| | | | N=378
Scott & Anderson, 1990 ^118^ Drug & Alcohol Review | 8 group practices participated. Patients self-administered the Health Survey Questionnaire, which was distributed either by mail or at primary care visits. | Standard Drink = 10 g ETOH (unit) | 1 Weekly consumption of ≥71 units;; 2 Received advice during previous year to cut down alcohol use | 384/11521 met weekly consumption criterion (3.3%);
| Women meeting the consumption criterion were invited to an in-person assessment interview, which included a one-week drinking diary. Eligible women were randomized after interview. | (Women only) | | 352/384 invited for assessment interview;
| | 21–71 units at least weekly | | 165/352 attended assessment interview;
| | | | 81/165 met consumption criteria in past week;
| | | | 72 enrolled/81 assessed (9 met exclusion criteria)
| | | | N=72

Notes:

“Assessment” is usually used in these trials to indicate more extensive questioning about alcohol use than is included at the “screening” phase; it differs from diagnostic assessment methods used to triage patients to levels of specialty alcohol treatment, such as those based on DSM-IV criteria for alcohol abuse and dependence.

The Time Line Follow Back (TLFB) is a procedure for ascertaining detailed daily descriptions of alcohol consumption, and is considered by some researchers to be the gold standard measuring alcohol consumption; it may, however, be too time-consuming for use during routine primary care visits.

In all except 3 studies, ^116,^ ^118,^ ^124^ alcohol use was assessed as part of a battery of other lifestyle behaviors in an effort to maintain participant and/or provider blinding as to the intent of the study or to diffuse initial patient resistance to addressing alcohol consumption. Almost all screening and screening-related assessments were done by research personnel, prior to the intervention visit, by self-assessment in the waiting room, ^117,^ ^124^ by mail, ^125^ by telephone or face-to-face interview, ^119,^ ^126^ or by a combination of these. ^111,^ ^116,^ ^118,^ ^120,^ ^122,^ ^127,^ ^128^ Studies used various instruments (AUDIT, CAGE, HSQ), and different subsets of questions to ascertain quantity, frequency, maximum use per occasion, and other alcohol-associated queries. In general, the types of patients identified for these intervention studies, particularly those conducted more recently in the United States, were less heavy, risky, or dependent drinkers than would be detected by use of validated screening tests, such as AUDIT, alone. Many studies also included patients if their quantity and frequency estimates exceeded recommended low-risk weekly thresholds for quantity (e.g., >12–14 drinks/week for men and > 7–9 drinks per week for women) or any indication of recent heavy episodic drinking (binge use).

Although the trials employed various recruitment and screening methods and procedures, several commonalities are apparent. First, several adapted the methods of Wallace et al. ^128^ This study used a two-stage screening and screening-related assessment procedure. The first stage involved a self-administered questionnaire, which embedded drinking questions among other health behavior items and which included both drinking quantity and frequency questions, the CAGE instrument, and an item allowing self-identification of having a drinking problem. The second stage, a longer, in-person interview, asked detailed questions about each day's drinking in the past week. Inclusion criteria for the first stage were based on usual consumption that exceeded gender-specific limits, on indications of alcohol-related symptoms or consequences (from the CAGE), or on self-description of having a drinking problem. Inclusion criteria at the second stage were based on total consumption in the past week, and those whose consumption exceeded gender-specific limits were included in the trial. Close variants of these two-step identification procedures were used by 5 subsequent studies. ^111,^ ^116,^ ^118,^ ^120,^ ^127^ The U.S. studies ^111,^ ^120,^ ^127^ often used a time-line followback (TLFB) procedure, considered by many to be the gold standard for assessing alcohol consumption. ^129^ This procedure is generally too time-consuming, however, for use in routine primary care.

Studies differed in the use of specific alcohol consumption measures (e.g., past week consumption vs. average consumption; or average consumption over different time frames), and in whether they specifically assessed for and included those with heavy episodic use (bingeing); when “bingers” were included, the definitions for these also varied. Studies also differed in whether or not they used established screening instruments (e.g., AUDIT, CAGE). The AUDIT was used as the primary identification tool in 2 studies, ^122,^ ^124^ but even in these it was supplemented with additional items or criteria to more clearly identify heavy usual consumption or heavy episodic drinking. Most studies used established screening instruments as adjuncts to various quantity, frequency, and use-per-occasion measures. ^120^ – ^122,^ ^126^ – ^128^

Two studies ^124,^ ^126^ also used the AUDIT score to exclude patients and/or refer them for evaluation for specialty alcohol treatment. None of the studies relied primarily on the CAGE instrument to identify risky drinkers, using it instead as a supplement to quantity-frequency items.

Among more recent U.S. studies that identified those with risks due to heavy episodic drinking as well as recent heavy average use, the screening yields of potentially eligible patients were 11–18% for patients undergoing screening and screening-related assessment as part of a two-step process. ^111,^ ^120,^ ^126,^ ^127^ Where data were available for the second step among these, about half of these patients were found to be eligible to receive primary-care based intervention after screening-related assessment. ^111,^ ^120,^ ^127^ This approximates the final screening yields reported (6.9–7.7%) for studies that recruited primary care patients from the waiting room, ^119,^ ^124^ and suggests that about 7% of general primary care patients might be candidates for these brief interventions. Although many studies did not report active refusal rates among participants, those that did suggest only small proportions refused. ^124,^ ^127^

## Key Question 3: What are adverse effects associated with alcohol use screening and screening-related assessment?

No data are available on any false-positive or negative effects that occur from generalized screening for alcohol misuse among patients. Another concern about potential harms related to screening for alcohol consumption revolves around uncertainties about whether patients may be offended. Greater dropout among those receiving brief interventions for risky alcohol use compared with controls in some studies ^124,^ ^126,^ ^128^ provides indirect evidence that such concerns may be warranted for small proportions of individuals. Alternatively, those receiving interventions that did not change their drinking may have dropped out due to embarrassment. However, we were unable to find research directly addressing potential adverse effects for either screening or brief interventions for alcohol problems.

## Key Question 4: Does behavioral counseling intervention in primary care reduce risky or harmful alcohol use in the targeted subgroup?

We located 5 meta-analyses or systematic evidence reviews published between 1994 and April 2002, that addressed very brief to extended interventions to reduce risky/harmful alcohol use. ^96^ – ^99,^ ^101^ All of these were judged to meet the USPSTF criteria for good systematic reviews, although they differed in questions addressed, methodology used, or research base available at the time of the review (see Appendix: Detailed Review of Other Recent SERs/Meta-Analyses). Kahan ^96^ reviewed the results of 11 randomized controlled trials (RCTs) on the effect of brief physician intervention with problem drinkers in a health care facility. The 4 with the highest validity scores ^116,^ ^118,^ ^128,^ ^130^ were all in primary care settings and showed decreases in weekly alcohol consumption (5–20 standard drinks per week) and higher assumption of moderate drinking levels (7–19%) for men. The results for women were mixed. Wilk ^97^ conducted a meta-analysis of 12 RCTs testing “brief” (less than 1 hour) alcohol interventions in heavy drinkers (heavy consumption, problem use, or those with mild alcohol abuse/dependence). Five of the 6 highest-quality trials ^116^ – ^118,^ ^128,^ ^131^ were all conducted in primary care settings; these 6 trials had a summary odds ratio for reduced or moderated drinking of 1.91 (95% 1.61–2.27) among heavy drinkers receiving “brief” intervention. In these trials, 44% of the intervention group achieved alcohol moderation compared to 28% of the controls. Poikolainen ^98^ conducted a meta-analysis of 7 RCTs to examine the effectiveness of “very brief” (5–20 minutes) versus “extended brief” (up to several visits) physician interventions on average alcohol intake or serum GGT changes in problem drinkers (excluding alcoholics) from primary care populations. Outcomes were analyzed by intervention intensity (“brief” versus “extended brief”) for treatment arms comparing men and women separately. Three groups of comparisons (for very brief interventions in men and women, and extended brief interventions in women) were statistically homogeneous, but only extended brief interventions in women showed a statistically significant decrease in alcohol intake (-51 grams/week or ½ drink/day). Dinh-Zarr, DiGuiseppi, and others ^101^ published a systematic review of 18 interventions for preventing injuries in problem drinkers (those with alcohol dependence, alcohol abuse, and hazardous use of alcohol) for the Cochrane Injuries Group. ^132^ None of the studies that met our inclusion criteria also reported injury outcomes. Moyer ^99^ completed a meta-analysis of 54 controlled clinical trials, 34 of which compared “brief” (4 or fewer sessions) interventions for alcohol use disorders with usual care controls or more extensive treatment. For studies with 6–12 months of followup, the average effect size for the composite of all drinking-related outcomes was .241 (95% C.I., .184, .299). The effect size for alcohol consumption in these same studies was .263 (95% C.I. .203, .323), but the results were statistically heterogeneous. As a convention, such effect sizes are generally interpreted as showing small-medium effects in favor of intervention. ^133,^ ^134^ Very few studies (5/34) reported followup greater than 1 year.

For our review, we identified 44 potentially eligible trials. We eliminated 27 studies that were poor-quality (n=17) ^115,^ ^131,^ ^135^ – ^149^ or were conducted in a non-primary care setting (inpatient setting or emergency department) (n=10) ^150^ – ^159^ (see Appendix: Table 10). As a result, we included 16 trials (12 targeting adults; 3 targeting pregnant women; 1 targeting adolescents) that met all inclusion/exclusion criteria for review. One adult study ^160^ met criteria but could not be included because data were not published at the time of this report (see Appendix: Table 12). We report on study results for each population group separately.

Table 12 Studies Awaiting Assessment and Ongoing Studies

Study Identification | Trial Name/Title | Participants | Interventions | Outcomes: Study Dates | Contact Information | Notes
[underlined: Studies Awaiting Assessment]
Higgins-Biddle & Babor | Cutting Back Program | 5 managed care organizations: 4 Staff models; 1 IPA | Systems-oriented approach to brief alcohol assessment and intervention in primary care—testing interventions by physicians or specialists (health educators, nurses) compared with usual care. | 3 month and 12 month | John Higgins-Biddle, Ph.D. | This study is in the data analysis phase and results may be available sometime after the summer of 2002 for consideration for this review. It is not clear whether the study meets criteria.
U. of Connecticut | | 15 primary care practices. | | change in drinks per week | 860-679-1590 | Results cannot be published prior to the outcome study's acceptance for publication.
Department of Community Medicine | | 50,000 pts screened | | | johnb@nso2.uchc.edu
Farmington CT | | 5000 patients identified as at risk drinkers.
Saitz, et.al. | Screening and Intervention in Primary Care (SIP) | Resident and faculty phsycians (n=41) in an academic medical center | Systems-oriented approach by providing the physicians with alcohol screening results & individualized recommendations at time of visit. | Proportion receiving discussions about alcohol use during the index visit | Richard Saitz, M.D., M.P.H. | This study has been submitted for publication. The author has shared a prepublication copy of the manuscript and it meets inclusion/exclusion and quality criteria.
Boston University | | 4,143 pts screened | | Change in patient drinks/drinking day and other alcohol measures at 6 months | 617-414-7399 | We may include it once the author received notice of acceptance.
School of Medicine and Public Health | | 14% identified at risk | | | rsaitz@bu.edu
Boston MA | | 312 subjects enrolled (55%)
[underlined: Ongoing Studies] (There are no ongoing studies at this time that we are aware of)

### Adults

The 12 fair- to good-quality trials of behavioral counseling interventions in adults are summarized in Table 8 of the Appendix. ^111,^ ^116^ – ^120,^ ^122,^ ^124^ – ^128^ All of the studies were randomized controlled trials except for one population-based study from Norway. ^125^ All but one study ^125^ were conducted in multiple primary care practices (ranging from 3–47 practices per study). Eight were conducted in community-based primary care settings, one in an academic medical center, ^127^ 2 in an HMO setting ^124,^ ^126^ and 1 in a range of outpatient settings in 8 countries. ^119^ Most studies involved a large number of participants (n>500). All except 2 ^119,^ ^125^ clearly targeted participants who were seeking or had recently received routine primary care. Women represented a third or more of study participants in all US studies but were less well represented in international studies that did not target females specifically. ^119,^ ^125,^ ^128^ Rates of non-White participation were not reported in many older international studies, and were low where reported in more recent US studies (4–27% non-White participation). ^111,^ ^124,^ ^126,^ ^127^

Table 8 Evidence for Adults

Study Identification | Participants | Interventions | Outcomes | Study Quality | Quality Rating/Comments including generalizability
Curry, 2003 ^126^ | 307 male and female patients with advanced primary care appointments who were willing to share screening survey information with their physician and had an AUDIT score of 15 or below, and had one or more of the following drinking patterns: mean ≥ 2 drinks/day in the past month OR ≥ 2 episodes of binge drinking (≥ 5 drinks/occasion) in the past month OR ≥ 1 episode of driving after 3 or more drinks in past month | Alcohol assessed along with other lifestyle behaviors in telephone interview prior to scheduled routine visit. | Outcomes not reported by gender. | Allocation concealment: Unclear concealment measures. | GOOD: Brief, multicontact intervention with minimal provider intervention burden and multiple follow-up contacts was clearly delivered and reduced at-risk drinking patterns at 12 months. No effects on average consumption.
Health Psychology | Age: 47 (M) | IG (151) received a very brief (1–5 minute) motivational message from their primary care provider and self-help manual at a routine visit with up to 3 telephone counseling calls from a research health educator. | Mean drinks/week reported at 12 mos: | Attrition bias: Intent-to-treat analysis with follow-up losses of 34 % (IG) and 22% (CG) but replacement of missing values using multiple imputation procedure. | Post-randomization non-differential exclusion of less than 10% of both groups due to failure to attend scheduled visits. Although differential loss to follow up between groups, analyses corrected for this using multiple imputation procedure for missing values.
RCT conducted in primary care clinics in an HMO in Washington State, USA. | % Female: 36% | 99% got provider intervention and materials; 87% got at least one call and 18% got all three. 87% recalled provider discussing alcohol after visit. | IG 10.6 | Patients and outcomes blinded: Satisfactory | [underlined: Generalizability:]
Standard Drink (DR) = 14 grams ETOH | % Nonwhite: 20% | Intervention included feedback, advice, goal-setting, assistance, tailoring and follow-up contact. | CG 10.6 | Baseline groups comparable; comparability maintained: Satisfactory. | Broadly includes risky/harmful adult drinkers with advance primary care appointments. Excludes AUDIT>15 and known alcoholics.
| Readiness to change measured: Yes | CG (n=156) received usual care after assessment. | p=.78 | Clearly delivered intervention: Yes | Usual care providers trained in academic detailing model (15–60 minutes). Intervention packet (script, flow sheet, materials) put on chart day of visit by research personnel. Research personnel provided phone calls.
| Baseline consumption: 14.9 mean DR/week | 25% recalled alcohol discussion with provider after the visit. | Binge/heavy episodes (% not bingeing at 12 mos): | | No incentives.
| | Harms not reported. | IG 86%
| | | CG 81% (p=.35)
| | | % reporting benefit (% reporting no at-risk drinking pattern [chronic drinking, binge drinking, or drinking & driving] at 12 mos): **
| | | IG 57% (n=151)
| | | CG 43% (n=156)
| | | (p=.048)
| | | ** outcomes adjusted for missing data at follow-up
Ockene, 1999 ^127^ | 530 adults (aged 21–70) seeking routine care with their primary care providers who had more than 2 health care visits in 6 months and who screened as “high risk drinkers” (i.e. men > 12 DR/week OR 5 or more DR/occasion once or more in the past month; women > 9 DR/week OR 4 or more DR/occasion once or more in past month; OR 2+/4 CAGE questions | Alcohol assessed along with other lifestyle behaviors in 2-step written survey & personal interview. | Change in mean DR/week at 6-mo. F/U: | Allocation concealment: Satisfactory. | GOOD: Brief, multicontact intervention with follow-up visit showed significant reductions in change in mean DR/week, even after adjustment for age, gender, and baseline drinking levels at 6 months.
Archives of Internal Medicine | 32.1% were female, 4.3% non-white, 33.6% smokers. | IG (n=274) received a brief (5–10 minute) face-to-face patient-centered alcohol intervention tailored to patient's problem areas (high usual and/or max/occasion consumption) from their usual primary care MD/NP at a routine visit and were asked to make a follow up appointment. | Total: | Attrition rate <10%: Satisfactory; Intent-to-treat analysis with replacement of missing values using baseline values. | Significant improvement in proportion drinking alcohol at safe levels.
RCT conducted in 4 primary cares internal medicine practice sites affiliated with an academic medical center in Massachusetts, USA. 46/47 attending MDs/NPs participated | Baseline alcohol consumption: 18.9 mean DR/week | 99% reported provider discussion & 59% had f/u visit within 6 mos. | IG -6.0 | Patients and outcomes blinded: Satisfactory. | Non-significant decreases in number of binge episodes/month and the proportion not binging at 6-month follow-up.
Standard Drink (DR) = 12.8 grams ETOH | | Intervention included advice, goal setting, assistance, tailoring & follow-up. | CG -3.1 | Baseline groups comparable; comparability maintained: Satisfactory. | Study adjusted for differences in unit of randomization (medical practice site) and analysis (patient).
| | CG (n=256) received general health pamphlet after assessment. | p=.003 | Clearly delivered intervention: Satisfactory. | [underlined: Generalizability:]
| | Harms not reported. | Female: | | Broadly includes risky/harmful drinking primary care patients.
| | | IG -6.8 | | Academic setting providers trained 2½ hours; Research staff did screening and attached results & intervention materials to chart for future visit(s).
| | | CG -3.5 | | No incentives.
| | | p=.003
| | | Male:
| | | IG -5.6
| | | CG -2.9
| | | p=.05
| | | Change in number of binge/heavy episodes/month:
| | | IG -1.8
| | | CG -1.0
| | | p=.09
| | | Binge/heavy episodes (% not bingeing at 6 months)
| | | IG 31.0% (77/248)
| | | CG 26.2% (61/233)
| | | (NS)
| | | Reporting benefit:
| | | % non-binge and safe weekly drinking:
| | | IG 38.7% (96/248)
| | | CG 28.3% (66/233)
| | | p<.05
Fleming, 1999 ^120^ | N=158 primary care patients aged 65 and older from 24 primary care practices recruited at regular visits. | Alcohol assessed in 2-step process of self-administered survey in waiting room (alcohol and other lifestyle behavior questions) and separate 30 minute face-to-face detailed alcohol-oriented interview by research personnel. | Results not reported by gender. | Allocation concealment: Satisfactory | GOOD: This brief, multicontact intervention among adults 65 and older reduced risky/harmful alcohol use at 12 months for all alcohol consumption measures, including those relating to binge use. Effects were even greater than seen for comparable intensity interventions in younger adults and occurred early (by 3 months) with maintenance. Baseline use was relatively low (15–16 drinks/week compared with many other studies). Family members corroborated alcohol use self-reports. The control group did not show reductions in measures of alcohol use as is generally seen in younger age groups after assessment.
Journal of Family Practice | (IG n=87; CG n=71) | IG (n=71) had two brief 10–15 minute visits scheduled one-month apart with their usual primary care physicians, with the clinic nurse calling them 2 weeks after each visit. | Mean DR/Week (# of drinks in previous 7 days, at 12 mos F/U): | Overall loss to follow up: 8% attrition. Intention-to-treat, complete cases only. Satisfactory | [underlined: Generalizability:]
RCT among patients in community-based primary care settings in Wisconsin, USA. | Eligibility: | 94% received at least one physician visit. | mean (SD; n) | Patients and outcomes blinded: Satisfactory | Broadly includes lower-level risky/harmful seniors (65+) visiting primary care. Excludes heavier users (>50 DR/week).
Standard drink (DR): 12–14 g alcohol | 1 Men consuming >11 drinks (>132 g alcohol)/week; women >8 drinks (>96 g alcohol)/week; or; 2 2 or more + on CAGE; or; 3 Binge drinking (men: 4 or more DR/occasion, women: 3 or more DR/occasion on 2 or more times in last 3 months). | Intervention included feedback, goal setting, assistance, and follow-up. | IG 9.9 (7.0; 78) | Baseline groups comparable; comparability maintained. Satisfactory. | Research personnel did all assessment. Usual care MDs in research network. Nurses conducted telephone follow-up.
| Exclusions: 1) Alcohol treatment program attendance or symptoms of alcohol withdrawal in previous year; 2.) Dr. advice to change alcohol use in previous 3 months; 3.) drank more than 50 drinks per week; 4. reported suicidal ideation | CG (n=824) received a general health booklet after assessment. | CG 16.3 (12.2; 67) | Intervention clearly delivered: Satisfactory | Providers paid $250 to participate.
| 53/158=34% women, modal age 65–75 yr, 75% married, 20% of women & 30% of men completed 4 yr college, 10% smoked, 15% used sedatives or narcotic medications. | Harms not reported | p<0.001 | | Patients paid $70 to complete study procedures.
| Baseline alcohol consumption: 16 mean DR/week | | Binge/heavy episodes # of binge drinking episodes in previous 30 days, at 12 mos F/U:
| | | mean (SD; n)
| | | IG 1.8 (6.0; 78)
| | | CG 5.4 (9.2; 67)
| | | p<0.005
| | | Binge/heavy episodes (% not bingeing at 12 months):
| | | IG 69.2% (54/78)
| | | CG 50.8% (34/67)
| | | p<0.025
| | | Proportion not drinking excessively at 12 months (≤20 DR/week for men, ≤13 DR/week for women):
| | | IG 84.6% (66/78)
| | | CG 65.7% (44/67)
| | | p<0.005
Fleming, 1997 ^111^ | All adult patients aged 18–65 visiting their primary care physician for regular care. | Alcohol assessed in 2-step process of self-administered survey in waiting room (alcohol and other lifestyle behavior questions) and separate 30 minute face-to-face detailed alcohol-oriented interview by research personnel. | Fleming 1997: | Fleming 1997: | GOOD: Brief, multicontact intervention by the usual care M.D. reduced alcohol consumption by men and women and reduced proportions bingeing at 12 months compared with no intervention. Women showed the greatest treatment effects.
Journal of the American Medical Association (12 month outcomes) | N = 774 (392 in IG 382 in CG) | IG (n=392) had two brief visits scheduled one-month apart with their usual primary care physicians, with the clinic nurse calling them 2 weeks after each visit. | Mean DR/week (# of drinks in previous 7 days, at 12 mos F/U): | Allocation concealment: Satisfactory, although not entirely clear.
| % Reporting having ever binged in last 30 days: | 76% completed the protocol and received both physician visits. | [mean (SD; n)] | Attrition bias: ≤ 10% + differential, but used intent-to-treat analysis with replacement of missing values.
| IG 86% | Intervention included feedback, advice, goal setting, assistance, and follow-up. | Total | Patients and outcomes blinded: Satisfactory.
| CG 87% | CG (n=382) received a general health booklet after assessment. | IG 11.48 (11.31; 392) | Baseline groups comparable; comparability maintained: Satisfactory.
| Inc/Exc Criteria: | Harms not reported. | CG 15.46 (12.93; 382) | Clearly delivered intervention: Yes.
| Inclusion: > 14 DR/week (men, > 11 DR/week (women) | | p<.001
| Exclusion: Pregnant women; ETOH treatment of withdrawal symptoms in past 12 mos; Received alcohol advice from Dr. in the last 3 mos; Drank > 50 DR/week; Suicidal thoughts | | Female:
| % Female: 38% | | IG 8.03 (8.26; 148)
| % Minority: 11+ % | | CG 13.20 (11.67; 144)
| Baseline Consumption (previous 7 days): 19.1 mean DR/week | | p<.001
| 85% binge drank in last 30 days | | Male:
| | | IG 13.62 (12.39; 244)
| | | CG 16.86 (13.49; 238)
| | | p<.005
| | | Change in mean DR/week (n):
| | | Female:
| | | IG -7.02 (148)
| | | CG -2.49 (144)
| | | Male
| | | IG -8.05 (244)
| | | CG -5.09 (238)
| | | Binge/heavy episodes (% reporting no binge drinking in the previous 30 days at 12 mos F/U):
| | | Total:
| | | IG 52.04% (204/392)
| | | CG 31.68% (121/382)
| | | p<.001
| | | Female:
| | | IG 52.7% (78/148)
| | | CG 34.72% (50/144)
| | | p<.025
| | | Male:
| | | IG 51.64% (126/244)
| | | CG 29.83% (71/238)
| | | p<.001
| | | % reporting benefit (proportion not drinking excessively at 12 mos F/U):
| | | Total:
| | | IG 84.69% (332/392)
| | | CG 68.85% (263/382)
| | | p<.001
| | | Female:
| | | IG 85.14% (126/148)
| | | CG 65.97% (95/144)
| | | p<.001
| | | Male:
| | | IG 84.43% (206/244)
| | | CG 70.59% (168/238)
| | | p<.005
Fleming 2002 ^108^ | | | Fleming 2002,
Alcoholism: Clinical & Experimental Research (48 month outcomes) | | | 48 mo. outcomes:
RCT conducted in 17 primary care community-based clinics with 64 physicians in Wisconsin, USA. | | | Mean DR/week:
Standard Drink (DR) = 12 g ETOH | | | Maintained 12-month results in IG (graphical display does not include numeric values)
| | | Binge/heavy episodes (% reporting no binge drinking (>5 DR) in the previous 30 days at 48 mos F/U):
| | | Total: (denom.)
| | | IG 36.2% (392)
| | | CG 29.6% (382)
| | | p<0.10
| | | Female:
| | | IG 38.5% (148)
| | | CG 32.6% (144)
| | | (NS)
| | | Male:
| | | IG 36.9% (244)
| | | CG 27.3% (238)
| | | p<0.05
| | | % reporting no “heavier drinking” (men> 20 DR and women >13 DR in previous 7 days (at 48 mos F/U):
| | | Total: (denom.)
| | | IG 77.6% (392)
| | | CG 73.6% (382)
| | | (NS)
| | | Female:
| | | IG 80.4% (148)
| | | CG 69.4% (144)
| | | p<0.05
| | | Male:
| | | IG 75.8% (244)
| | | CG 76.0% (238)
| | | (NS)
Manwell, 2000 ^121^ | Manwell, 2000: | | Manwell 2000 Outcomes: | Manwell, 2000: | In a subgroup study, women of reproductive age (18–40), alcohol consumption and binge drinking episodes were reduced at 48 months follow-up. Women in the intervention group who subsequently became pregnant may reduce their weekly and per occasion intake more than similar women in the control group.
Alcoholism: Clinical and Experimental Research | Females of childbearing age (aged 18–40) visiting their primary care physician for regular care. | | Mean DR/week (# of drinks in previous 7 days reported for females aged 18–40 at 12 and 48 mos. F/U): mean (SD;n) | Allocation concealment: Unclear concealment measures. | [underlined: Generalizability:]
(Manwell 2000 is a sub study of the original Fleming 1997 study followed for 48 months) | N= 205 (103 in IG, 102 in CG) | | [underlined: 12 mos.] | Attrition bias: Adequate (there is intention-to-treat analysis, follow-up losses are equal to or less than 20%, and there is replacement of missing values) | Broadly includes lower-level risky/harmful drinkers visiting primary care. Excludes heavier users. (>50 DR/week).
RCT conducted in 17 primary care community-based clinics with 64 physicians in Wisconsin, USA. | % Reporting having ever binged in past 30 days: | | IG 7.36 (5.97; 103) | Patients and outcomes blinded: Satisfactory. | All assessment was by research personnel. Research network usual care providers were trained 1 hour initially with two 30-minute booster sessions. Nurses conducted telephone follow-up.
Standard Drink (DR) = 12 g ETOH | IG 96% | | CG 11.81 (11.53; 102) | Baseline groups comparable; comparability maintained: Satisfactory. | Providers were paid $300 to participate and received three trainings before and spaced throughout recruitment.
| CG 93% | | p=.01 | Clearly delivered intervention: Yes. | Patients were paid $50 to complete required procedures.
| Inc/Exc Criteria: | | [underlined: 48 mos.]
| Inclusion: > 11 DR/week or > 4 drinks/occasion or 2 or more positive responses to CAGE | | IG 7.48 (7.63; 103)
| Exclusion: Pregnant women; ETOH treatment of withdrawal symptoms in past 12 mos; Received alcohol advice from Dr. in the last 3 mos; Drank > 56 DR/week; Suicidal thoughts | | CG 9.94 (10.83; 102)
| % Female: 100% | | p=.27
| % Minority: 15 % | | % reporting benefit: NR
| Baseline Consumption (previous 7 days) 19.2 mean DR/week
Senft 1997 ^124^ | 516 adults (age 21+) visiting for primary care who met broad inclusion criteria for hazardous drinking (AUDIT score 8–21 or 2 AUDIT Q/F item scores ≥5 and exceeding maximum/ occasion (6 or more DR) at least weekly). Dependent drinkers excluded (and AUDIT ≥ 21). | Alcohol assessed only in one-step self-administered survey. | Mean DR/week at 12-mo. F/U (calculated from total drinks in past 3 months): | Allocation concealment: Satisfactory. | GOOD: Brief intervention with no effects on average consumption, bingeing, and modest intervention effects, primarily on total drinking days (for women) at 12 months.
American Journal of Preventive Medicine. | Mean (SD) | IG (n=260) received a 15-minute face-to-face contact consisting of 30 seconds of advice from their usual PC provider & a 15-minute motivational interviewing-based session with a research health counselor after a routine visit. | Total: Mean (n) | Attrition rate = 20%, differentially greater in IG, and those continuing were more educated. | Mean DR were reduced at 6 months (p=.04) but not at 12 months (p=.12) IG were somewhat more likely to benefit (drink within recommended limits at 12 months).
RCT conducted in 3 large primary care group practices in an HMO in the Pacific Northwest (USA); | Age 41.9(13.6) yr | 70% received intended advice & counseling. | IG 13.1 (196) | Replacement of missing value using baseline values was used in sensitivity analyses for outcomes. No impact on reported results. | No effect on max DR/day or prevalence of heavy drinking.
Standard drink (DR) = 0.5 oz ETOH | 28% female | Intervention included advice, goal setting, & assistance. | CG 14.9 (215) | Patient and outcome assessment blinding: Satisfactory. | [underlined: Generalizability:]
| 17% nonwhite | CG (n=256)—Usual care after assessment. | p=0.13 | Baseline groups comparable; comparability maintained: Satisfactory. | Broadly includes risky/harmful adult drinkers in primary care. Excludes dependent drinkers.
| 50% smokers, | Harms not reported. | Female: | Clearly delivered intervention: Satisfactory | Research staff delivered assessment & most of intervention. Usual care providers prompted with script to give advice only.
| 59% finished some college. | | IG 8.9 (53) | | No incentives.
| 59% were seriously considering cutting down on drinking. | | CG 9.2 (68)
| Baseline alcohol consumption: (approx) 16.5 mean DR/week; 27% exceeded max/occasion. | | p=0.43
| 5.0 mean DR/drinking day; | | Male:
| Baseline AUDIT score: 10.6 (3.4) mean (SD) | | IG 14.7 (143)
| | | CG 17.5 (147)
| | | p=0.08
| | | (Change from baseline not reported.)
| | | Binge/heavy episodes (% reporting no binge drinking [6+ DR at least weekly]):
| | | IG 77%
| | | CG 77% (ns)
| | | Reporting benefit (% drinking no more than 3 DR/day for men and 2 DR/day for women):
| | | IG 80.0% (158/198)
| | | CG 73.1% (158/216)
| | | p=.07
Anderson & Scott, 1992 ^116^ | Male patients aged 17–69 attending or registered with the practices. | Alcohol assessed only in 2-step written survey and personal interview. | Change in mean DR/week at 12 month F/U: (n) | Allocation concealment: Satisfactory | GOOD: This brief intervention showed improved low-risk drinking, improved bingeing and nearly significant changes in mean DR/week. Relatively high attrition adjusted in analyses by replacing missing values with baseline consumption levels.
British Journal of Addiction | N=154 (80 in IG, 74 in CG) | IG (n=80) received 10-minute face-to-face visit with usual PC provider at special visit scheduled after assessment. | IG -15.7 (80) | Overall loss to follow up: | [underlined: Generalizability:]
RCT conducted in 8 group community-based primary care practices in England. | Inc/Exc Criteria: | Intervention delivery measures not reported | CG -9.2 (74) | IG: 31%. CG: 39% | Broadly includes heavier drinking males (up to 105 DR/week primary care patients. 41% of patients with abnormal dependence scores.
Standard Drink (DR) = 10gr ETOH | Inclusion: Weekly consumption of 350gr (35 DR) or more | Intervention included advice and feedback. | p=.06 | Intention to treat with missing values replaced using baseline values. | Brief (15–30 minute) usual care provider training. Alcohol assessment conducted entirely by research staff outside the clinic, including face-to-face structured assessment interview by PhD researcher.
| Exclusion: Weekly consumption of 1050gr (105 DR) or more; Received advice during the previous year to cut down on alcohol use. | CG (n=74)—after assessment, nothing unless requested. | Binge/heavy episodes (% not bingeing at 12 mos F/U): (n) | Patients and outcomes blinded: Satisfactory | No incentives.
| % Female: 0% | Harms not reported. | IG 77.50% (62) | Baseline groups comparable; comparability maintained: Satisfactory.
| Age: 45.1 +/- 1.9 (SEM) | | CG 60.81% (45) | Intervention clearly delivered: Satisfactory
| Social Class I-IIIn: 32.5% | | p<.05
| % Minority: NR | | Proportion benefiting (% attaining low risk drinking as measured by HSQ Q/F 22 or fewer DR/week): (n)
| Baseline Consumption (past 7 days), mean (SE): | | IG 17.50% (14)
| 52 (1.4) mean DR/week | | CG 5.41% (4)
| | | p<.05
Nilssen, 1991 ^125^ | Population survey of city inhabitants ages 12–62 (men) or 12–56 (women) included questions about alcohol consumption used to identify a “risk group,” with a) elevated GGT (50–200 men, 45–200 women): b) alcohol drinking at least 2–3 times per week; or c) single occasion drinking equivalent to 1 bottle of wine 1–2 times per month. | Alcohol assessed along with other lifestyle behaviors in self-administered questionnaire to be filled out & mailed in after lab, survey and physical examination focused on coronary heart disease risk factors. | Alcohol consumption at 15 mo. follow-up, mean (SD; n) grams/day: | Allocation concealment: Not reported. | FAIR: Brief intervention and brief, multicontact interventions both reduced alcohol consumption compared with no intervention. Report inadequately covers allocation concealment and blinding for outcome assessment. Not clear who delivered the interventions and the potential for contamination.
Preventive Medicine | Medical records reviewed to exclude persons with alcoholism, hepato-biliary diseases, major psychiatric disorders, or taking antiepileptic medication. Risk group invited to examination & interview. | IG1 (113) invited by letter to re-examination for an “elevated blood test.” At re-exam received info on elevated GGT causes (including alcohol) and repeat GGT from undesignated person. Mailed repeat GGT results and invited to re-screen at one year. | IG1 15.6 (16.3; 107) | Overall loss to follow-up: | [underlined: Generalizability:]
RCT conducted in Tromso, Norway. | N=338. Randomized to 2 intervention groups and 1 control group. | Intervention delivery not reported. | IG2 13.5 (14.1; 105) | 5%, satisfactory. Intention-to-treat complete cases only. | This population-based study targeted only “early stage problem drinkers” (those with moderately increased GGT and self-reported increased alcohol intake) and did so among people already willing to participate in a heart disease risk assessment. Excluded known alcoholics. Not conducted in “usual” primary care, but outpatient clinic setting with continuity of care.
Standard drink: NR | 14% female, 12 yr education, 56% smoking (approx.) | Intervention included feedback and follow up. | CG 39.2 (35.9; 108) | Patients and outcomes blinded: Unclear. | No incentives.
| Mean age: 41.0 (men), 42.7 (women) | IG2 (n=113) were invited by letter to re-examination for an “elevated blood test.” At re-exam, intervention focused on alcohol consumption and completed a standardized assessment instrument (early version of AUDIT). GGT was redrawn & repeat visits w/lab tests offered until GGT normalized. | p<0.001) | Baseline groups comparable; comparability maintained: Unclear.
| Baseline Consumption: NR | Harms not reported. | Binge/heavy episodes: NR | Intervention clearly delivered: Unclear.
| | 25% had one follow-up visit; 51% two; and 24% three or more. | % reporting benefit: NR
| | Intervention included feedback, assistance and follow-up.
| | CG (n=112) had no alcohol-related contact.
| | Harms not reported.
Wallace, 1988 ^128^ | N= 909 adults (aged 17–69) attending or registered with primary care clinics. | Alcohol assessed in 2-step process of self-administered survey in waiting room (alcohol and other lifestyle behavior questions) and separate face-to-face detailed alcohol-oriented interview by research nurse. | Outcomes reported separately by gender: | Allocation concealment: Satisfactory | GOOD: Reasonably high attendance rates (62%) for second step assessment among patients identified as drinking above recommended levels in survey. This brief, multicontact intervention by the usual care M.D. reduced alcohol consumption by men and women and the proportion drinking excessively at 12 months compared with no intervention. Over half of patients attended two or more visits.
British Medical Journal | Inc/Exc Criteria: | IG (n=450) were contacted by their dr. to schedule one-to-two visits scheduled one-month apart with their usual primary care physicians, with 3 further visits offered at dr's discretion. | Change in mean DR/week (SE; n) | Overall loss to follow up: | [underlined: Generalizability:]
RCT conducted in 47 group practices as part of Medical Research Council's (MRC) research network, averaging 10,000 patients in a few urban, mostly rural and small urban locations in England & Scotland. | Inclusion: Consumption of more that 35 units/week (males) or 21 units/week (females); OR not drinking excessively but answered 2+/4 CAGE questions or self-assessed drinking problems (25% of these). | 83% of men and 92% of women completed at least one visit; while 57% of men and 65% of women attended at least twice. 25% of women and 18% of men had 4 or more visits. | Females: | IG: 17%. CG: 11% | Broadly includes heavier drinking adult primary care patients. Excludes those recently advised or with >>GGT.
Standard Drink (DR) = 1 unit (not further defined) | Exclusion: Medical advice regarding drinking in last year; GGT > 150 IU/l; Serious illness. | Intervention included feedback, advice, goal setting, assistance, and follow-up. | IG 11.5 (1.6; 130) | Intention to treat with missing values replaced using baseline values. | Usual care providers in research network. Provider training not reported. Research nurse did assessment; self-administered assessment component as well.
| % Female: 29.1% | CG (n=459) received a general health booklet after assessment and no alcohol advice unless GGT over 150 IU/l or requested by patient. | CG -6.3 (2.0; 137) | Patients and outcomes blinded: Satisfactory | No incentives.
| % Minority: NR | Harms not reported. | p<.05 | Baseline groups comparable; comparability maintained: Satisfactory.
| Baseline Consumption: weekly alcohol consumption at health survey interview): | | Males: | Intervention clearly delivered: Satisfactory
| Females: mean (SE) | | IG -18.2 (1.5; 318)
| 35.1 (1.5) mean DR/week | | CG -8.1 (1.6; 322)
| Males: | | p<.001
| IG 62.2 (1.6) mean DR/week | | Binge/heavy episodes: NR
| | | Proportion benefiting (reported as proportion not drinking excessively at 12-mo F/U interview): (n)
| | | Females:
| | | IG 47.69% (62)
| | | CG 29.20% (40)
| | | p<.05
| | | Males:
| | | IG 43.71% (139)
| | | CG 25.47% (82)
| | | p<.001
Maisto, 2001 ^122^ | 301 patients ≥ 21 years of age; AUDIT ≥ 8 OR ≥ 16 std DR/week (men) or ≥ 12 std DR/week (women). | Alcohol assessed along with other lifestyle behaviors in a 2-step self-administered questionnaire and face-to-face interview and limited physical exam. | Change in mean DR/drinking day (95% CI; n) at 12-mo. F/U | Allocation concealment: satisfactory. | FAIR: Two intensities of motivational interviewing-based research staff delivered interventions (brief and brief, multicontact) showed null effects with reductions in alcohol consumption among interventions and control. Fairly intensive assessment phase include limited physical exams. All participants' doctors received assessment results and no measures of how/if that information was acted upon.
Journal of Studies on Alcohol | Age: mean 45.5 (SD 15.2) | IG-1 (n=100) received 10–15 minutes of “brief advice” from the research intervention staff with intentionally limited patient input immediately following assessment. | IG1 -1.55 (-2.32, -0.79; 74) | Attrition bias: 23% loss to follow-up. Intention-to-treat complete cases only. | [underlined: Generalizability:]
RCT conducted in 12 primary care sites, USA. | % Female: 32% | 93% got complete brief advice session. | IG2 -1.30 (-1.96, -0.64; 73) | Patients and outcomes blinded: Unclear blinding. | Broadly includes primary care patients with risky/harmful drinking. Excludes those with acute alcoholic symptoms/recent treatment.
Standard Drink (DR) = 0.6 oz ETOH | % Minority: 23% | Intervention included feedback, advice, and goal setting. | CG -1.48 (-2.11, -0.85; 85) | Baseline groups comparable; comparability maintained: Satisfactory. | Research staff provided all of intervention. No definite or clear provider role. Participants paid for all assessments except initial one.
| Baseline consumption: | Assessment results were forwarded to their Drs.. | Change in mean DR/week | Clearly delivered intervention: Satisfactory.
| 5.5 DR/drinking day (IG1) | IG2 (n=101) received a 30–45 minute “motivational enhancement” session from the research interventionist (emphasizing empathy & reflective listening to reduce barriers and decrease desirability) and two 15–20 minute booster sessions. | All:
| 5.3 DR/drinking day (IG2) | 91% had at least one and 69% received all three intervention sessions. | IG1 -8.3
| 6.3 DR/drinking day (CG) | Intervention included feedback, advice, goal setting, assistance, and follow-up. Assessment results were forwarded to their doctors. | IG2 -5.5
| | CG (n=100) assessment results were forwarded to their doctors only. | CG -3.6
| | Harms not reported. | (NS)
| | | Binge/heavy episodes: NR
| | | % reporting benefit: NR
WHO Brief Intervention Study Group, 1996 ^119^ | Adults 18–70 accrued through diverse methods across clinical sites, many were probably help-seeking. | Alcohol assessed along with other lifestyle behaviors in a 20-minute face-to-face interview before visit. | Outcomes reported by gender: | Allocation concealment: Satisfactory. | FAIR: Very brief and brief interventions reduced alcohol consumption in males at an average of 9 months (6–19 months) follow-up compared with assessment only. Among females, all groups significantly reduced their consumption at follow-up without between group differences. Limited information to evaluate study quality regarding baseline comparability of groups, maintenance of comparability and measures of intervention delivery. Potential for contamination, as different interventions were delivered by the same interventionists.
American Journal of Public Health | N=1559 (503 in IG1, 565 in IG2, 491 in CG) | IG1 (n=503) received 5 minutes of health advice from a “health advisor” (46% RNs, 18T MD, 35% other) as part of a routine primary care visit. | Average cL of alcohol/day in prior 6 mos, at 9-mos. F/U: | Attrition bias: Adequate (25% overall loss to follow-up) Intention-to-treat with missing data replaced with baseline values. | [underlined: Generalizability:]
RCT conducted in 8 centers including various medical settings in 8 nations (Australia, Kenya, Mexico, Norway, Wales, Russia, USA, and Zimbabwe) | Inc/Exc Criteria: | Intervention delivery measures not reported. | Males: | Patients and outcomes blinded: Satisfactory. | Broadly includes multi-cultural heavier drinking primary care/health care patients. Excludes known or suspected alcoholics or very high consumers.
Standard Drink (DR) = 1.5 cL ETOH (14g or 0.5 oz) | Inclusion: Mean alcohol consumption > 50 grams/day (men) or > 32 grams/day (women); Heavy drinking (6 or more drinks/occasion) | Intervention included feedback, advice, and goal setting. | IG1 5.29 | Baseline groups comparable; comparability maintained: | “Provider training” reported among range of clinical health advisor's delivering assessment/intervention.
| Exclusion: Prior Rx for serious mental illness, liver damage, or alcohol dependence; | IG2 (n=565) received 15 minutes of brief counseling from the health advisor also addressing behavioral techniques as part of the routine visit. Some sites offered three follow-up visits. | IG2 5.18 | Satisfactory at baseline; unclear if maintained. | No incentives.
| Pregnancy; Told by Dr/other health professional to abstain; Past or recent morning drinking; Recent very high consumption (120g/men or 80g/women); Social/residential instability | Intervention delivery measures not reported. | CG 6.29 | Clearly delivered intervention: Unclear.
| % Female: 19.2 | Intervention included feedback, advice, goal setting, assistance, follow-up (subset). | p<.001
| % Minority: NR | CG (n=491) received assessment only. | Females:
| Baseline consumption: NR | Harms not reported. | IG1 2.99
| | | IG2 3.39
| | | CG 3.80
| | | (NS)
| | | Average cL of alcohol per drinking occasion:
| | | Males:
| | | IG1 10.16
| | | IG2 10.01
| | | CG 11.23
| | | p<.01
| | | Females:
| | | IG1 5.96
| | | IG2 6.27
| | | CG 6.83
| | | (NS)
| | | Mean drinks/week: NR
| | | Binge/heavy episodes: NR
| | | % reporting benefit: (patients reporting drinking within recommended weekly limits [males: ≤3–4 DR/day, ≤4–5 days/week, or 24 cL of ethanol/week; females: ≤2–3 DR/day, ≤4–5 days/week, or 13.3 cL ethanol/week] at 12 mos):
| | | Females:
| | | IG1 43%
| | | IG2 39%
| | | CG 35%
| | | (NS)
| | | Males:
| | | IG1 43%
| | | IG2 43%
| | | CG 35%
| | | p<.05
Richmond, 1995 ^117^ | Adults (18–70) attending clinics were screened using HFQ assessing alcohol, smoking, exercise, & weight. | Alcohol assessed along with other lifestyle factors in the waiting room prior to a routine visit. | Note: Outcomes for only IG1 and IG2 groups reported here because intervention implementation issues clouded differences between IG2 & IG3. | Allocation concealment: Inadequate concealment measures | FAIR: Very brief intervention (IG-2) and assessment only (IG-1) reduced their consumption at 12 months with no significant differences between conditions. The true control condition was not followed at 12 months. Possibly inadequate allocation concealment strategy. Baseline differences in for alcohol dependence and alcohol problems, which were controlled for in some analyses. Intervention delivery was sub-optimal: only 49% in the extended brief (IG-3) getting more than the brief. Possible contamination in the assessment only (IG-1) condition by physician advice/discussion.
Addiction | N=378 (93 in IG1, 96 in IG2, 96 in IG3, 93 in CG) | IG1 (n=93) had the results of their alcohol assessment placed on the chart for their visit with their usual primary care provider. | Outcomes reported by gender: | Attrition bias: Intention-to-treat complete cases only. | [underlined: Generalizability:]
CCT conducted in 40 GP practices in Australia. | Inc/Exc Criteria: | Intervention delivery/contamination not assessed. | Mean drinks/week** (reported 7-day consumption at 12 mo F/U) (SD; n): | Patients and outcomes blinded: Satisfactory. | Broadly includes heavier drinkers attending primary care. Excludes severely dependent/severe alcohol-related problems. 38% report moderate dependence.
Standard Drink (DR) = 10 g ETOH | Inclusion: > 35 standard | IG2 (n=96) had the results of the assessment along with brief (5 minutes) within-visit physician advice and a self-help manual. | Females: | Baseline groups comparable; comparability maintained: Unsatisfactory. | Usual care providers “trained.” Receptionist or research assistant did patient screening and prompted physician (3 minutes). Research assistant did detailed assessment (15 minutes) to exclude ineligible patients.
| DR/week (men), >21 standard | Intervention delivery not assessed. | IG1 21.5 (12.7; 30) | Clearly delivered intervention: Unclear. | No incentives.
| DR/week (women) | IG3 (n=96) received the same brief advice intervention with four additional 15–20 minute provider visit also delivered feedback, assistance, goal setting, and follow-up scheduled at 1 week, 1 month, 3 months and 5 months. | IG2 24.2 (16.9; 31)
| Exclusion: Severe alcohol dependence (Ph score > 10); | 49% had one or more follow up visits; 51% got only single visit like intended for IG-2. | Males:
| Severe alcohol related problems (MAST > 20); Previous or current ETOH Rx.; Any ETOH consumption medically contradicted. | CG (n=93)—assessment results not put on chart. Not followed at 12 months. | IG1 36.2 (24.5; 31)
| % Female: 43% | Harms not reported. | IG2 39.3 (22.0; 39)
| Age: 38 (14.3) | | **no significant group by time interactions based on repeated measures analysis
| Baseline consumption: (previous 7 days) 38.5 (23.1) mean DR/week. | | Binge/heavy episodes: NR
| | | % reporting benefit in either category**: (proportion not exceeding recommended drinking levels [calc] at 12 mos [recommended levels ≤ 28 units for men, ≤ 14 units for women]):
| | | IG1 21.5%
| | | IG2 22.9%
| | | **based on intent-to-treat analysis, differences not significant
Scott & Anderson, 1990 ^118^ | 72 female patients aged 17–69 attending or registered with the practices who had weekly consumption of 21–71 units of alcohol/week. | Alcohol assessed only in 2-step written survey and personal interview. | Change in mean DR/week at 12 month F/U (n): | Allocation concealment: Unclear. | FAIR: Brief intervention after fairly extensive assessment phase showed null effects as both groups comparably reduced alcohol consumption. Intervention delivery was uncertain and control may have been contaminated. Inadequate power. Baseline differences in dependence.
Drug & Alcohol Review | 100% female | IG (n=33) received 10-minute face-to-face visit with usual PC provider at special visit scheduled after assessment. | IG -11.6 (33) | Attrition bias: Adequate. | [underlined: Generalizability:]
RCT conducted in 8 community-based primary care practices in England. | 67% reported social class I-IIIn | Intervention delivery measures not reported. | CG -10.0 (39) | Intention-to-treat and replacement of missing values using baseline values. | Broadly includes heavier drinking female (up to 71 drinks/week) primary care patients - >50% of sample with abnormal dependence score.
Standard Drink (DR) = | % Minority: NR | Intervention included advice and feedback. | Bingeing/heavy episodes (% not bingeing [14+ units on 2+ occasions in previous 3 months] at F/U): | Patients and outcomes blinded: Satisfactory. | Limited (15–30 minute) provider training. Alcohol assessment conducted entirely by research staff outside the clinic, including face-to-face structured assessment interview by PhD researcher.
1 unit=10 grams ETOH | Age: 44.4 +/- 2.4 (M, SEM) | CG (n=39)—after assessment, nothing unless requested. | IG 87.9% (29/33) | Baseline groups comparable; comparability maintained: Baseline difference in dependence. | No incentives.
| Alcohol use in last week by interview: 35.3 +/- 1.6 units | Harms not reported. | CG 84.6% (33/39) | Clearly delivered intervention: Unsure.
| 73% of IG had abnormal alcohol dependence scores (41% of CG, p<.02) | | Reporting benefit:
| Baseline consumption: 35.3 mean DR/week | | % attaining low risk drinking (HSQ 22 or fewer DR/week)
| | | IG 27.3% (9/33)
| | | CG 25.6% (10/39)

The trials generally targeted high-average and/or heavy occasional (binge) users. Alcohol consumption limits for risky/harmful use varied among studies but were lower for women in most studies. ^111,^ ^116^ – ^120,^ ^122,^ ^127,^ ^128^

Table 13 of the Appendix, shows the baseline consumption for participants across studies by gender when available. “Corrected” columns reflect consumption levels adjusted for whether a standard drink is defined as containing 12 grams or 14 grams of alcohol, the usual range of standard drink sizes in the US. Even after “correction” it is clear that earlier non-US studies ^116^ – ^118,^ ^128^ tended to recruit heavier baseline alcohol users among both men and women (men 37–44 mean DR/week at baseline; women 25 mean DR/week at baseline) than later US studies; these earlier studies also included some drinkers with “less severe” but definite dependence symptoms compared with more recent US studies, which tended to exclude heavier or dependent drinkers.

Table 13 Baseline Consumption of Alcohol Among Risky/Harmful Drinkers Recruited for Interventions in Primary Care (Mean DR/week) *

Study | Baseline Consumption Reported in Study in DR/week Mean (SD) | “Corrected” Baseline Consumption Mean DR/week**
| | Low estimate (14gr/DR) | High estimate (12gr/DR)
Senft ^124^ | 16.5 | —— | ——
Ockene ^127^ | 16.6 (12.4) | —— | ——
Scott & Anderson ^118^ (females only) | 35.3 (SE=1.6) | 25.1 | 29.4
Maisto ^122^ | 20.6 | —— | ——
Curry ^126^ | 13.6 (SE=0.83) | —— | ——
Richmond ^117^ | 38.5 (23.1) | 27.5 | 32.1
WHO ^119^ | NR | N/A | N/A
Fleming 1997 ^111^ | M 21.7 (12.8) | —— | ——
| F 15.0 (10.0) | —— | ——
Nilssen ^125^ | NR | N/A | N/A
Fleming 1999 ^120^ | 15.5 (7.6)
Anderson & Scott ^116^ (males only) | 52 (SE=1.4) | 37.2 | 43.4
Wallace ^128^ | M 62.2 (SE=1.6) | 44.4 | 51.8
| F 35.1 (SE=1.5) | 25.1 | 29.3

* Baseline consumption for all participants or for least intensive intervention groups only when baseline consumption data not reported for all participants.

** Baseline consumption in studies where 1 DR=10gr of ETOH recalculated to approximate the alcohol content of US studies (12–14gr of ETOH).

Studies varied in their assessment of drinking levels because the definition of a standard drink varies internationally. Many earlier studies from outside the United States ^116^ – ^118^ defined a standard drink as 10 grams alcohol (1 unit), while more recent US studies defined a standard drink as somewhere between 12–14 grams of alcohol or about 0.5–0.6 oz of alcohol. ^111,^ ^120,^ ^122,^ ^124,^ ^127^ The WHO International Study defined a standard drink as 14 grams of alcohol. Some did not explicitly define a standard drink, ^126^ and so were assumed to use the same standard as other studies from the same country for calculations comparing baseline consumption across studies.

### Interventions

Studies primarily tested interventions delivered all or part by the patient's usual primary care physician. Exceptions to this were the use of research personnel, ^122^ “health advisors” (46% RNs, 18% MDs, 35% other), ^119^ or unspecified intervention personnel. ^125^ Among the interventions involving a patient's usual primary care physician, some used the physicians to deliver initial and any repeated intervention contacts ^117,^ ^118,^ ^127^ while others also used health educators/counselors, ^124,^ ^126^ or clinic nurses. ^111,^ ^120,^ ^128^ However, most interventions also involved contact with a research person to determine study eligibility through screening and screening-related assessment prior to intervention.

According to our intensity definition (see Appendix, Table 2), 2 studies evaluated very brief interventions, ^117,^ ^119^ 6 studies ^116,^ ^118,^ ^119,^ ^122,^ ^124,^ ^125^ evaluated brief interventions, and 7 evaluated brief multi-contact interventions. ^111,^ ^120,^ ^122,^ ^125^ – ^128^ Fifteen intervention arms were contributed by the 12 studies (i.e., since three studies adequately tested more than one arm of varying intervention intensities against controls). ^119,^ ^122,^ ^125^ Control conditions involved screening/assessment only, ^116,^ ^118,^ ^119,^ ^125,^ ^126^ screening/assessment followed by usual care, ^124^ provision of a general health pamphlet after screening/assessment, ^111,^ ^120,^ ^127,^ ^128^ or screening/assessment results recorded on the chart ^117^ or forwarded to a physician. ^122^ We considered that very brief or brief interventions (n=8) were those that could more feasibly be incorporated into current routine primary care with relatively minimal changes, while brief multi-contact interventions (n=7) were those likely to need more substantial primary care reconfiguration and/or systems support in addition to provider behavior change for incorporation into routine care.

Rates of intervention delivery provide an estimate of whether the tested intervention was delivered adequately enough to fairly evaluate it. Most fair- to good-quality studies reported to what degree the intervention was delivered as intended, although several studies did not, ^116,^ ^118,^ ^119,^ ^125^ and 1 study with multiple intervention arms reported intervention delivery only for the most intensive intervention. ^117^ For the extended brief intervention arm of this study, only 49% of patients got anything beyond the very brief initial intervention contact, diluting the possibility of adequately evaluating the more intensive approach. Some studies reported reasonable completion rates for the entire protocol ^111,^ ^122,^ ^124,^ ^127^ varying from 60–76%, while others reported fewer participants completing the entire protocol. ^126,^ ^128^ Interpreting the lower delivery rates for these 2 studies is complicated because their protocols involve “up to” a certain number of contacts at the discretion of the provider and/or patient. Completion rates for the first 2 contacts of these protocols were 60% or above. Some studies reported much higher completion rates (91–94%), ^120,^ ^122,^ ^126,^ ^127^ but these rates usually reflected only the initial contact of an intervention.

Outcomes. All studies included estimates of intervention impact on average alcohol consumption at 6–12 months followup. One study ^111^ reported longer-term (48-month) followup in 2 separate reports. ^108,^ ^121^ Intervention groups had significantly lower average alcohol consumption in six of the 12 studies, ^111,^ ^119,^ ^120,^ ^125,^ ^127,^ ^128^ and the rest consistently reported minimal to modest decreases in average drinks/week in both interventions and controls that were not statistically significantly different. ^116^ – ^118,^ ^122,^ ^124,^ ^126^

Among the very brief and brief single contact interventions, ^116^ – ^119,^ ^122,^ ^124,^ ^125^ one study testing both very brief and brief interventions ^119^ (with optional followup at some centers) reported significantly reduced average alcohol consumption among those receiving either intervention compared to controls at 12-month followup. Another study testing both brief and brief multi-contact interventions ^125^ found that both types of interventions significantly reduced alcohol consumption compared to controls, although the potential for contamination between conditions wasn't clear. Most of the very brief or brief intervention studies did not report intervention delivery except 2 ^122,^ ^124^ with adequate to good intervention delivery for the single component intervention. Therefore lack of intervention delivery may confound the failure to find treatment effects for most brief or very brief interventions. Among seven adequately tested brief multi-contact interventions, ^111,^ ^120,^ ^122,^ ^125^ – ^128^ five ^111,^ ^120,^ ^125,^ ^127,^ ^128^ reported that participants had significantly lower average alcohol consumption than controls at 12 months ^111,^ ^125,^ ^128^ ^120^ or 6 ^127^ months. The other 2 showed no difference in mean drinks (DR)/week among intervention and control participants. ^122,^ ^126^

Long-term alcohol consumption was measured in 1 study ^111^ for the entire cohort ^108^ and for a subset of women of child-bearing age. ^121^ Men and women in the intervention group maintained the reduction in alcohol consumption (mean DR/week) achieved by 12-months through 48-month follow up. By 48 months, differences between intervention and control were no longer statistically significant because of late onset (between 36 and 48 months) reductions in control group usage primarily among men. The relatively delayed reduction in control consumption to levels achieved by the intervention group at 12 months could reflect (late) regression to the mean, the natural history of alcohol consumption, or the cumulative effect of yearly followups. ^108^ For a subset of women of childbearing age (18–40), ^111^ average alcohol consumption significantly decreased in interventions compared with controls by 12 months. Reduced levels were maintained among intervention patients over 48 months, but were no longer statistically significantly different at 48 months because of late onset (between 24–28) reductions among controls.

To further summarize the effect sizes and consistency of the alcohol consumption results, Figure 4 of the Appendix shows the net change in mean drinks/week (DR/week) for brief interventions (listed first) and brief multi-contact interventions that reported intention-to-treat baseline and followup levels of consumption for intervention subjects compared with controls. ^111,^ ^116,^ ^118,^ ^120,^ ^122,^ ^126^ – ^128^ Two studies were rated fair quality ^116,^ ^122^ while the rest were rated good quality. The effects range from a net reduction of about 1 to 10 mean DR/week. Among brief multi-contact trials with statistically significant effects, ^111,^ ^120,^ ^127,^ ^128^ patients receiving the intervention consumed 2.9 to 8.7 fewer drinks per week than those in the control conditions. Among effective trials that report results by gender, 2 ^111,^ ^127^ of 3 ^111,^ ^127,^ ^128^ show similar or better effects among women.

Figure 5 of the Appendix shows the net percentage-point reduction in mean DR/week between interventions and controls at followup. The 3 brief intervention arms are listed first, followed by the brief multi-contact interventions. Drinkers receiving effective brief multi-contact interventions reduced their drinking between 13 and 34 percentage points compared with controls. The largest effect sizes (30–34%) were seen among women in the Fleming 1997 study and older adults (65+). ^120^

Figure 5. Net percentage point reduction in mean drinks per week^*^ † * To calculate the percentage point reduction in average consumption from baseline for each group, we divided the reduction in mean drinks/week by the baseline mean drinks/week and multiplied by 100. We then subtracted the percentage reduction in the intervention group from the percentage reduction in the control group to obtain the net percentage point reduction in mean drinks per week. ^†^ n= the number in the intervention and control groups for this comparison.

Binge/heavy episodic drinking was reported in a subset of good studies ^111,^ ^116,^ ^120,^ ^124,^ ^126,^ ^127^ and 1 fair-rated study ^118^ (n=7) (see Appendix: Figure 6). Three good quality studies ^111,^ ^116,^ ^120^ that also reported reducing average alcohol consumption showed reduced numbers of binge users in intervention compared with control, while the rest showed no differences. Across studies, binge use remained fairly common. For example, in trials with at least 49% binge users at baseline, ^111,^ ^120,^ ^127^ binge drinkers remained fairly common (31–69%) among intervention participants.

Figure 6. Percent Not Binge Drinking at Follow-up

Three fair-quality ^117^ – ^119^ and 7 good-quality studies ^111,^ ^116,^ ^120,^ ^124,^ ^126^ – ^128^ reported some measure of the proportion that benefited from the intervention compared to controls (see Appendix: Figures 7 & 8). These were defined differently across studies, but addressed the proportion drinking within safe/recommended limits, ^116^ – ^120,^ ^124^ the proportion not drinking excessively, ^111,^ ^128^ the proportion with safe weekly intake and no bingeing, ^127^ and the proportion not reporting any at-risk drinking pattern (including driving after drinking 3 or more drinks). ^126^ Among 6 ^111,^ ^116,^ ^120,^ ^126^ – ^128^ of the 7 good quality studies, significantly more intervention participants than controls achieved recommended drinking patterns. Across these studies, 10–19% more intervention participants than controls achieved recommended or safe drinking limits. Three studies that did not show a beneficial effect ^117,^ ^118,^ ^124^ were similarly ineffective as measured by average drinking consumption and bingeing outcomes where available. One study ^119^ showed significant results for males only.

Figure 7. Percent Achieving Recommended Drinking Levels/Patterns at Followup (Total)

Few fair- to good-quality studies in adults addressed intervention effects besides alcohol consumption and alcohol-related behaviors. These are addressed in Key Question 5.

### Pregnant Women

We identified 3 fair- to good-quality behavioral counseling interventions in primary care settings that targeted women making prenatal visits. ^161^ – ^163^ One additional study ^149^ was excluded from the review because it failed to meet at least fair internal validity criteria. All 3 included studies were randomized controlled trials that assessed alcohol consumption during the perinatal period. Table 9 of the Appendix records the details of these studies, which are summarized in this section.

Setting and Participants. All 3 studies were conducted in the United States among women making routine prenatal visits. Two ^161,^ ^162^ were in university health center settings, while 1 ^163^ was in a public health maternity clinic. Two of the studies were small (<100 participants) ^161,^ ^163^ and 1 was medium-sized (n=250). ^162^ All clearly targeted women making prenatal visits. Ethnic diversity was greater in these studies than in the general adult brief intervention studies reviewed above, with the 2 smaller studies including over 60% ethnic minority participants (the other included 20% minority). Participants in the 2 smaller studies were also similar in terms of average age of participant (early to mid-20s), two-thirds single or divorced, and unemployment or low-income status. Participants in the larger study by Chang et al. ^162^ were older (approximately 30 years), and only 16% were single or divorced. The studies varied in extensiveness of alcohol assessment, ranging from 2 hours, ^162^ to 1 hour, ^161^ to a brief screening questionnaire. ^163^ The 2 smaller studies included women who reported any alcohol consumption in the previous month, while the larger study included women who were positive on the T-ACE screening instrument. A standard drink was defined in the Handmaker study ^161^ as approximately 0.5 ounces of alcohol; neither of the other 2 studies defined a standard drink. At baseline, reported average number of drinks in the past week (calculated from monthly figures when necessary) ranged from 2.25 in the Handmaker study ^161^ to 7–11 in Reynolds ^163^ (for intervention and control groups, respectively). Mean drinks per drinking day were reported in the Chang study ^162^ as ranging from 0.6 to 0.9 in the intervention and control groups, respectively. Handmaker et al. ^161^ presented evidence of underreporting of alcohol consumption to medical providers, compared to reports in research interviews. These authors also suggest that peak blood alcohol concentration (BAC) is the best indicator of potentially harmful fetal exposure to alcohol, and recommend the addition of this measure rather than solely relying on reported average consumption. The estimate of BAC in their study was based on self-reported drinks, however, not on breath or blood analysis.

Interventions. Two of the studies included face-to-face counseling interventions, while the other ^163^ combined a 10-minute educational session with a self-help manual. In the Handmaker et al. study, ^161^ women in the intervention group were given a 1-hour motivational interview at a visit subsequent to study enrollment. The primary intervention goal was to heighten the women's perceptions of fetal risks from alcohol consumption while simultaneously supporting their self-efficacy to reduce or quit drinking. The interview followed principles of brief motivational interventions as described in Miller and Rollnick. ^164^ Chang et al ^162^ delivered a 45-minute structured counseling intervention immediately following the 2-hour comprehensive assessment interview. The intervention focused on identifying the women's drinking goals, motivation, drinking risk situations, and alternatives to alcohol. Non-clinical personnel delivered the interventions in both the Handmaker and Chang studies. ^161,^ ^162^ The Reynolds study was innovative in using clinic-based health educators to orient participants to a 9-step self-help manual, which was given to the participants to complete over a 9-day duration. All of these interventions would be considered “extended” interventions under our intensity definition (see Appendix, Table 2), although the Reynolds et al ^163^ intervention used only 10 minutes of clinic staff time. All used an intention-to-treat design. Usual care control conditions were used except in the Handmaker study, ^161^ in which controls were sent an informational letter about alcohol risks during pregnancy that also encouraged them to see their health care providers.

Outcomes. Followup intervals were relatively short in all 3 studies (1–2 months postpartum), and follow-up rates were excellent (92–99% in Reynolds ^163^ and Chang, ^162^ respectively) or acceptable (81% in Handmaker ^161^ ). Two of the studies were consistent in failing to show significant intervention impacts on indicators of average alcohol consumption. ^161,^ ^162^ The Reynolds study ^163^ reported marginally statistically significant differences favoring the intervention group on mean total drinks in the previous month (0.36 versus 1.14 in intervention and control groups, respectively, p<.06), and on percent abstinent (88% versus 69% in intervention and control groups, respectively, p<0.058). Subgroup analyses in the Handmaker ^161^ study revealed an interaction between peak BAC level at baseline and treatment group, with women who had the highest BACs being more likely to respond to the intervention.

### Adolescents

For adolescents in a health care setting, we identified only 1 intervention study that met inclusion criteria. Werch et al., ^165^ rated “fair” based on our quality criteria, conducted an RCT of a brief preventive intervention among students attending school sports physical examinations. Study participants were 178 7^th^ to 9^th^ grade students—60 from an urban school, 74 from a suburban school, and 44 from a rural school. Participants were fairly evenly divided on gender (51.7% male); nearly 75% were White and 13.5% were African American. At baseline, 55.1% had tried alcohol in their lives; 28.1% had consumed alcohol during the year prior to the study. Screening consisted of a “dip-stick” saliva bogus pipeline procedure to improve validity of self-reported alcohol use, and the 10-minute “Youth Alcohol and Drug Survey,” assessing alcohol use. Alcohol use measures included intention to drink in the next 6 months, drinking during the prior 7 days, drinking during the prior 30 days, and heavy drinking (5 or more drinks in a row) in the prior 30 days.

Intervention participants received the STARS for Families intervention - a 20-minute telephone call by a nurse in the days following the sports exam, including a discussion of the risks, purpose of the communication, prevention messages, and recommendation to avoid future alcohol use. Ten prevention postcards were mailed twice weekly to parents/guardians, asking them to take a few minutes to read and talk with their child about the important fact found on each card, designed to help the child stay away from alcohol.

Loss to followup across groups was minimal (8%), and investigators used intention-to-treat analytic procedures. At 6-month followup of the pooled sample of rural and suburban youth, intervention youth were significantly less likely to intend to drink than controls (5.5% vs. 19.2%), were less likely to drink in prior 30 days (3.6% vs. 17.3%), and were less likely to have consumed 5 or more drinks in a row during the prior 30 days (0.0% vs. 9.6%). There were no statistically significant differences between urban intervention and control groups. Intervention costs were estimated to be $16.13 per student.

## Key Question 4a: What are the essential elements of efficacious interventions?

Within the adult intervention trials reviewed for KQ4, intervention intensity appeared to explain some of the heterogeneity in the results of the adult trials: 2 of 6 very brief or brief interventions had statistically significant effects on average alcohol consumption, while 5 of 7 trials of more intensive interventions did. Similarly, other alcohol outcomes appeared more likely in brief multi-contact interventions compared with the less intensive interventions. To identify other factors that may be associated with heterogeneity in the results of these trials, we examined how well other intervention elements that have been cited as important to these interventions ^40,^ ^55,^ ^64,^ ^105^ distinguished between studies with positive and negative effects on average alcohol consumption.

### Goal-Setting

The majority of adult intervention arms ^111,^ ^117,^ ^119,^ ^120,^ ^122,^ ^124,^ ^126^ – ^128^ reported goal-setting as an explicit part of their intervention approach. Of the 4 that did not, 3 did not show an intervention effect on average consumption ^116^ – ^118^ and one did. ^125^

### Multiple Versus Single Contacts

Five of the single-contact interventions ^116^ – ^118,^ ^122,^ ^124^ showed little or no intervention effect on average consumption, while 2 others ^119,^ ^125^ showed intervention effects comparable to other more intensive interventions. Both of these studies tested multiple less and more intensive intervention arms in the same study. Nillsen ^125^ tested brief and very brief interventions and possible contamination was not addressed. Although the WHO tested very brief and brief interventions, it is interesting to note that there was optional followup in some sites for the latter intervention arm. Since the followup was optional, we chose to categorize the study as brief single contact.

Among those studies with followup (multiple intervention contacts), all offered repeat provider visits ^111,^ ^117,^ ^119,^ ^120,^ ^125,^ ^127,^ ^128^ except two; one used telephone contact ^126^ and the other had repeat contacts with a research interventionisits ^122^ All those with repeat visits except the study arm that was insufficiently delivered ^117^ reported significant intervention effects on average consumption.

### Matching or Tailoring Interventions

Intervention details were not sufficiently reported to allow us to evaluate this question regarding stage-of-change or other tailoring assessments.

### Ongoing Assistance

Among the 6 studies that delivered ongoing assistance and were effective in reducing average alcohol consumption, ^111,^ ^119,^ ^120,^ ^125,^ ^127,^ ^128^ all delivered multiple contacts that extended over 1–12 months to at least some of their patients. Intervention elements included feedback, advice, goal setting, and repeated assistance involving a variety of approaches (information on drinking prevalence and risks, motivational interviewing, problem-solving barriers to change, drinking dairies for self-monitoring, workbooks, drinking cue awareness activities, drinking agreements or “RXs.”) and at times a variety of other health care personnel (nurses, health educators/counselors). ^111,^ ^119,^ ^120^

### Patient Motivation and Problem Awareness

Studies did not report consistent measures of problem orientation or motivation among patients.

## Key Question 5: Are there other positive outcomes from behavior counseling interventions to reduce risky/harmful alcohol use?

Few fair- to good-quality studies in adults addressed intervention effects such as health care utilization, ^111,^ ^116,^ ^118,^ ^121,^ ^124,^ ^166^ or cost effectiveness. Of all the studies that examined health care utilization, only 1 found reduced self-reported hospital days among males in the intervention group compared with controls at 12 months of followup. ^111^ At longer-term followup (48 months) in the same study, males and females in the intervention group reported significantly fewer hospital days compared with controls. ^108^ These data reflected self-reported estimates of use rather than analyses of administrative data, as did 1 other study. ^124,^ ^166^

Out of 100 articles identified in the literature search for economic studies addressing counseling interventions to reduce risky/harmful alcohol use, 14 were retrieved, and 12 of these were excluded: seven were not original economic analyses, ^167^ – ^173^ two included only costs and no measures of effectiveness ^174,^ ^175^ two examined non-primary care interventions ^176,^ ^177^ and one reported measures of effectiveness for interventions that could not be disaggregated. ^178^ In addition to the two studies identified through the literature search, ^179,^ ^180^ another article relating to one of these studies was identified through expert contact ^108^ and a third study from examining reference lists. ^181^ These three original cost-effectiveness studies were abstracted and reviewed by a separate cost working group team, but interpretation of their results was limited because of noncomparability between studies in definitions of drinking misuse/problems and intervention designs, and lack of inclusion of non-medical (e.g., quality of life) as well as medical outcomes. Additionally, most studies lacked a societal perspective in terms of both benefits and effects. Despite these limitations, these studies tended to show that brief interventions are either cost savings or have cost-effectiveness ratios that compare favorably to other commonly endorsed interventions. Firm conclusions from these studies are premature, however, given the limitations cited, particularly the variability in inputs, definitions, and differences in assumptions between studies.

## Key Question 6: What are adverse effects associated with behavioral counseling interventions for risky/harmful alcohol use?

As discussed above, higher attrition rates among intervention compared with control groups in some studies suggests that, for some individuals, alcohol misuse interventions may be embarrassing or even offensive. There are no data on adverse effects of treatment, including theoretical reduction in “benefits” from moderate use among patients who may be benefiting from non-risky use. Also, some drinkers with more severe abuse or dependence might be undertreated and harmed if guided towards moderation rather than abstinence. However, literature searches targeted to potential harms retrieved no articles, and no information to address these questions was reported in the screening reviews or the intervention studies included in our review.

## Key Question 7: What healthcare system influences are present in effective screening, and screening-related assessments and interventions to reduce risky/harmful alcohol use and/or its outcomes?

Interventions function in a “context” of the network of resources, services, and conditions in the larger health care system and community. ^182^ To evaluate generalizability (of individual studies on brief alcohol interventions in primary care) and feasibility (of this approach in the current and future health care system), some level of context evaluation considers factors related to the health care team, the service system and environment, and the broader community.

Within the adult intervention studies reviewed for Key Question 4, the little information reported about contextual factors concerned the health care team and, to some extent, the health care system and environment.

### Settings/Health Care System Factors

Four ^111,^ ^120,^ ^127,^ ^128^ of the 12 adult intervention studies were conducted in more research-oriented practice settings, which may have influenced provider adherence to research protocols. Two studies were delivered in HMO settings, ^124,^ ^126^ 1 in an academic setting, ^127^ and the remainder of US studies in community-based primary care. To identify potential study participants for screening/assessment, 2 used upcoming appointment systems, ^126,^ ^127^ while others used practice registries. ^116,^ ^118,^ ^128^

### Personnel Involved with the Study

Research staff conducted the screening and screening-related assessments to identify at-risk patients prior to intervention in nearly every study; most of these processes were fairly time-intensive (>30 minutes) and done outside routine care encounters. Only 4 studies used the waiting room to entirely qualify patients; ^116^ – ^118,^ ^124^ others began a longer process with waiting-room patients. ^111,^ ^119,^ ^120,^ ^122^ As indicated, usual care physicians were involved in most studies. In some studies research staff were also involved in the delivery of some (or all) of the intervention, ^119,^ ^122,^ ^124,^ ^126^ while in others non-physician health care staff were involved. ^111,^ ^120^ Research staff often performed important support functions, such as prompting the provider and supplying intervention materials to the chart. ^122,^ ^124,^ ^126,^ ^127^ None reported using electronic medical record support.

### Provider training

Provider training sessions were specifically reported in many studies ^111,^ ^116^ – ^119,^ ^126,^ ^127^ and were relatively brief (15 minutes to 2.5 hours). More recent studies reported both initial and ongoing training. ^111,^ ^127^

### Incentives

Many (9/12) studies did not report using incentives for participating providers or patients, although a few studies did. ^111,^ ^120,^ ^122^

### Summary

Many studies were conducted with usual care primary physicians among a reasonably broad swath of patients recently or currently presenting for care. Some studies were not conducted in research-affiliated primary care ^116^ – ^118,^ ^122,^ ^124,^ ^126^ and may provide more accurate estimates of the effects to be expected in usual primary care. All interventions required sufficient systems support in the provision of screening/assessment services and, in some cases, provider prompting. It would not be realistic to expect even the most modest effects from interventions that did not have such systems in place as well.