# Methods

## Analytic Framework and Key Questions

Using methods of the US Preventive Services Task Force (USPSTF) ^100^ we developed an analytic framework and 7 key questions (KQs) (see Appendix: Figure 1) to guide this review process. KQ1 addressed the direct evidence that behavioral counseling interventions reduce morbidity or mortality. KQ2 concerned the screening methods used to identify the target populations for alcohol-related behavioral counseling interventions in primary care. KQ3 concerned harms and costs of identification of alcohol use disorders. KQ4 addressed the impact of primary care identification and intervention on risky or harmful alcohol use, and any other benefits (KQ5) or harms (KQ6) from such interventions. KQ7 examined the context for these interventions by looking at health care system influences that help or hinder appropriate patient identification and intervention delivery.

Figure 1. Analytic Framework & Key Questions

Does Behavioral Counseling Intervention for Alcohol-Related Risks and Problems In Adults Improve Health Outcomes and Decrease Morbidity and Mortality?

Given the emphasis of the last USPSTF recommendations on screening, and the availability of new research on brief counseling interventions, we concentrated on the effects of brief interventions in primary care on alcohol use, on other intermediate outcomes, and on health outcomes (KQs 1 and 4). We did not systematically review the evidence on the efficacy of screening tools nor look for direct evidence that screening alone improves outcomes.

A team from the Cost Working Group of the USPSTF conducted searches of MEDLINE, HealthSTAR, PsychInfo, and the British National Health Service's Economic Evaluation Database (see Appendix: Table 6). Titles and abstracts were reviewed by two investigators, and studies were excluded if they were clearly not original economic analyses reporting both costs and effects of primary-care based counseling interventions for risky/harmful alcohol use. All other studies were retrieved and reviewed, along with articles identified by experts and manual searching of reference lists. Included studies were critically appraised by all cost work group team members and abstracted using a standard form. Quality was rated according to previously developed criteria (see Appendix: Form 1), and the entire working group discussed study features, key parameters, assumptions, results and quality before making its general conclusions.

Table 6 Literature Search Terms

PsychInfo
1 | exp alcoholism/ or exp Alcoholism/ or problem drink$.mp.
2 | exp alcohol intoxication/ or exp alcohol drinking patterns/ or alcoholic intoxication.mp.
3 | (binge drinking or heavy drinking or excessive alcohol or risky drinking or harmful drinking or hazardous drinking or excessive drinking or episodic drinking or heavier drinking).mp.
4 | 1 or 2 or 3
5 | limit 4 to treatment & prevention
6 | (counsel$ or treatment or patient education or intervention$).mp.
7 | exp rehabilitation education/ or exp drug education/ or exp drug abuse prevention/ or prevention.mp.
8 | 6 or 7
9 | 4 and 8
10 | 5 or 9
11 | (randomized controlled trial$ or randomi$ or placebo$ or double blind or single blind or volunteer$ or control$ or prospective$).mp.
12 | exp treatment effectiveness evaluation/
13 | (clinical trial$ or research design$ or comparative stud$ or prospective stud$ or random allocation$).mp.
14 | 11 or 12 or 13
15 | 10 and 14
16 | limit 15 to (human and english language)
17 | limit 16 to yr=1994-2002
MEDLINE
1 | (problem drink$ or alcohol$ or binge drinking or heavy drinking or excessive alcohol$ or risky drinking or harmful drinking or hazardous drinking).mp.
2 | exp drinking behavior/ or exp alcohol-related disorders/
3 | (heavy episodic$ or alcoholic intoxication).mp.
4 | 1 or 2 or 3
5 | limit 4 to (clinical trial or clinical trial, phase i or clinical trial, phase ii or clinical trial, phase iii or clinical trial, phase iv or controlled clinical trial or randomized controlled trial)
6 | randomized controlled trials/ or randomized controlled trial$.mp. or randomi$.mp.
7 | random allocation.mp. or exp clinical trials/ or double-blind method$.mp.
8 | (single-blind method$ or clinical trial$ or placebo$).mp.
9 | ((single or double or treble or triple) adj (blind$ or mask$)).mp.
10 | exp research design/ or research design$.mp. or comparative study/ or exp evaluation studies/ or evaluation stud$.mp.
11 | (follow-up studies or follow up stud$).mp. or prospective studies/ or prospective stud$.mp. or control$.mp. or prospective.mp. or volunteer$.mp. [mp=title, abstract, registry number word, mesh subject heading]
12 | 6 or 7 or 8 or 9 or 10 or 11
13 | 4 and 12
14 | 5 or 13
15 | limit 14 to (human and english language)
16 | counseling/ or exp health education/ or (interview$ and motivat$).mp.
17 | “Early Intervention (Education)”/
18 | intervention studies/ or intervention.mp. or alcoholism/pc or exp drinking behavior/pc or prevent$.mp. or counsel$.mp.
19 | 17 or 18
20 | 15 and 19
21 | limit 20 to yr=1994-2001
HealthSTAR
1 | (problem drink$ or alcohol$ or binge drinking or heavy drinking or excessive alcohol$ or risky drinking or harmful drinking or hazardous drinking).mp.
2 | exp drinking behavior/ or exp alcohol-related disorders/
3 | (heavy episodic$ or alcoholic intoxication).mp.
4 | 1 or 2 or 3
5 | limit 4 to (clinical trial or clinical trial, phase i or clinical trial, phase ii or clinical trial, phase iii or clinical trial, phase iv or controlled clinical trial or randomized controlled trial)
6 | randomized controlled trials/ or randomized controlled trial$.mp. or randomi$.mp.
7 | random allocation.mp. or exp clinical trials/ or double-blind method$.mp.
8 | (single-blind method$ or clinical trial$ or placebo$).mp.
9 | ((single or double or treble or triple) adj (blind$ or mask$)).mp.
10 | exp research design/ or research design$.mp. or comparative study/ or exp evaluation studies/ or evaluation stud$.mp.
11 | (follow-up studies or follow up stud$).mp. or prospective studies/ or prospective stud$.mp. or control$.mp. or prospective.mp. or volunteer$.mp. [mp=title, abstract, registry number word, mesh subject heading]
12 | 6 or 7 or 8 or 9 or 10 or 11
13 | 4 and 12
14 | 5 or 13
15 | limit 14 to (human and english language)
16 | counseling/ or exp health education/ or (interview$ and motivat$).mp.
17 | “Early Intervention (Education)”/
18 | intervention studies/ or intervention.mp. or alcoholism/pc or exp drinking behavior/pc or prevent$.mp. or counsel$.mp.
19 | 17 or 18
20 | 15 and 19
21 | limit 20 to yr=1994-2001
Cinahl
1 | exp alcoholism/ or exp Alcoholism/ or problem drink$.mp.
2 | exp alcohol intoxication/ or exp alcohol drinking patterns/ or alcoholic intoxication.mp.
3 | (binge drinking or heavy drinking or excessive alcohol or risky drinking or harmful drinking or hazardous drinking or excessive drinking or episodic drinking or heavier drinking).mp.
4 | 1 or 2 or 3
5 | limit 4 to treatment & prevention
6 | (counsel$ or treatment or patient education or intervention$).mp.
7 | exp rehabilitation education/ or exp drug education/ or exp drug abuse prevention/ or prevention.mp.
8 | 6 or 7
9 | 4 and 8
10 | 5 or 9
11 | (randomized controlled trial$ or randomi$ or placebo$ or double blind or single blind or volunteer$ or control$ or prospective$).mp.
12 | exp treatment effectiveness evaluation/
13 | (clinical trial$ or research design$ or comparative stud$ or prospective stud$ or random allocation$).mp.
14 | 11 or 12 or 13
15 | 10 and 14
16 | limit 15 to (human and english language)
17 | limit 16 to yr=1994-2002
Cochrane Controlled Trials Registry (CCTR)
1 | Alcohol*
2 | Drink*
3 | 1 or 2

## Search Strategy

Key questions 1, 4, 5, and 7. We searched the Cochrane Database of Systematic Reviews and Database of Research Effectiveness (DARE) (2001, issues 2 and 3; 2002 issue 1) using an inclusive search strategy (alcohol* or drink*) to identify recent high-quality systematic reviews addressing brief interventions to reduce risky/harmful alcohol use in primary care. We found five well-conducted recent systematic reviews of interventions ^96^ – ^99,^ ^101^ and reviewed their bibliographies to ascertain any studies not identified through our separate searches of other primary databases (described below). Unpublished studies were located through expert contacts and referrals. We also retrieved relevant literature reviewed in the 1996 Guide to Clinical Preventive Services. ^64^ We searched MEDLINE, Cochrane Controlled Clinical Trials, PsychInfo, HealthSTAR, and CINAHL databases from 1994 through April 2002, using search strings detailed in Table 6 of the Appendix, and results from this search (integrated with articles retrieved from outside sources) are shown (see Appendix: Figure 2). One investigator reviewed 4331 non-duplicative titles and abstracts, and a second investigator reviewed a random 35% of titles/abstracts for concordance. Approximately 95% agreement was found, and no articles that met review inclusion criteria were discrepantly coded by the two reviewers. For included studies, no matter the source, one primary reviewer abstracted relevant information using data-abstraction forms. All key data that appear in the evidence tables (see Appendix: Tables 9 & 10) were checked by a second reviewer and articles excluded for quality or relevance appear in Table 10 of the Appendix. Quality of the articles was graded using the USPSTF criteria, ^100^ supplemented by guidelines on evaluating study randomization, attrition, and intention-to-treat analyses from the Cochrane Drug and Alcohol Group. ^102^

Table 9 Evidence for Pregnant Women

Study Identification | Participants | Interventions | Outcomes | Study Quality | Quality Rating/ Comments
Chang, 1999 ^162^ | N: 250 pregnant women. | Following a comprehensive, 2-hour assessment interview focusing on alcohol (conducted by a research assistant), participants randomly assigned to IG or CG. | In person follow-up interview, approximately 2 months post-partum. | Allocation concealment: Satisfactory. | GOOD.
Addiction | Baseline Consumption (reported as mean number of DR/drinking day, currently, excluding abstainers): | IG participants met with first author immediately after the assessment interview for a 45-minute brief intervention. This structured interview contained the following elements:; 1 review of participant's general health and pregnancy;; 2 review of life-style changes since pregnancy began, including alcohol consumption;; 3 identification of participant's drinking goals during pregnancy and reasons for these goals;; 4 identification of circumstances in which drinking was tempting;; 5 identification of alternatives to alcohol in tempting situations;; 6 summarizing session and emphasizing 4 key points of drinking goals, motivation, risk situations, alternatives to alcohol. | For interval between initial assessment and delivery: | Attrition bias:
RCT conducted in US resident and family practices in an academic setting. | Mean (SD) | All participants informed of US Surgeon General's recommendation that prenatal abstinence is the most prudent drinking goal. | Decrease in DR/drinking day, | Intention-to-treat analysis was performed and there were very few losses to follow-up (1%).
Standard Drink (DR) = NR | IG 1.5 (1.2) | Given take-home manual, “How to prevent alcohol-related problems.” | IG -0.3 | Patients and outcomes blinded: Satisfactory.
| CG 2.1 (1.5) | No further followup. | CG -0.4 | Groups differ in some ways, but differences are handled in analysis.
| Inc/Exc Criteria: | Intervention delivery not reported. | Difference not statistically significant (#s NR) | Clearly delivered intervention:
| Inclusion: Gestational age ≤ 28 weeks; Positive T-ACE (modified tolerance question - feeling high w/2 drinks, scored = 2); First 250 consecutive eligible women who agreed were randomized. | CG: No special contact reported; presumably usual care. | Episodes of drinking | Yes.
| Exclusion: Gestational age > 28 weeks; No alcohol consumption in 6 months before study participation; Miscarriage between survey & telephone interview; Non-English speaking; Intended abortion or false pregnancy; Current substance abuse treatment; Other (9% of those excluded) | Harms not reported. | IG 0.7
| % Female: 100% | | CG 1.0
| % Minority: 22% | | (p=0.12)
| % Smokers: 8% | | For interval between delivery and followup assessment:
| 40% met DSM III-R criteria for lifetime alcohol abuse or dependence (none met criteria for current) | | Regression analysis showed no effect of study group on alcohol consumption
| 28% met DSM III-R criteria for lifetime drug abuse or dependence (none met criteria for current) | | Secondary, sub-group analyses:
| Motivation Composite: NR | | Among those abstinent at baseline (n=142), % who drank in antepartum period: p<.05
| | | IG 72%
| | | CG 86%
| | | Among drinkers at baseline (n=105), overall decrease of 1.2 DR/drinking day, but no group differences.
| | | Proportion benefiting: NR.
Reynolds, 1995 ^163^ | N: 78 pregnant women with prenatal appointments. | IG: “Self-help” intervention included a 10-minute session conducted by an educator, and introduction to a self-help manual. The manual included 9 steps, to be completed over 9 days. | Quit rate (reported by self report questionnaire): | Allocation concealment: Satisfactory. | GOOD
International Journal of the Addictions | Baseline consumption (reported as mean DR/month): | Based on social cognitive theory, intervention included goal setting, self-monitoring, perceived self-efficacy, negative outcome expectancies of drinking, positive outcome expectancies of quitting, and ability to identify & cope with drinking situations. | IG 88% | Attrition bias: Intention-to-treat analysis performed and very few losses to follow-up (8%).
RCT conducted in US public health primary care clinics. | IG 44 | No tailoring explicitly reported. | CG 69% | Patients and outcomes blinded: Satisfactory.
Standard Drink (DR) = NR | CG 28 | No further followup. | Chi-square difference test non-significant @ p=.058. | Baseline groups comparable and maintained: Satisfactory.
| Inc/Exc Criteria: | CG: usual care, including routine information on alcohol's fetal effects, brief discussions with clinic staff, and video about prenatal care. | DR/month (reported as an estimate of the amount of alcohol consumed in the past month): | Clearly delivered intervention:
| Inclusion: Pregnant women who had consumed alcohol in past month; ≤ 25 weeks gestation. | Intervention delivery: all IG received educational session and self-help manual, 97% received reminder phone call. 5 CG members (13%) read part of the self-help manual. | IG 0.36 | Yes.
| Exclusion: > 25 weeks gestation; Non-drinkers. | Harms not reported. | CG 1.14
| % Female: 100% | | t-test non-significant @ p=.06
| % Minority: 69% | | Proportion benefiting: NR
| 56% with income less than $25K annually
| Motivation Composite: NR
Handmaker, et al. 1999 ^161^ | N= 42 pregnant women | After consenting to study participation, women who reported consuming at least 1 drink in past month completed 1-hour alcohol assessments, including the Brief Drinker Profile (BDP) and a timeline reconstruction of drinking in past 2 months. | Alcohol consumption outcomes from Brief Drinker Profile assessment, at 2 months followup | Allocation concealment: Satisfactory. | FAIR.
Journal of Studies on Alcohol | Baseline Consumption: | IG (n=20) given a 1-hour motivational interview at home or other convenient site, subsequent to the assessment, conducted by research personnel (first author). | 3 outcomes analyzed: total # of standard drinks in past 2 months, peak blood alcohol concentration (BAC), total days abstinent. | Attrition bias: Intention-to-treat analysis appears to have been performed, but is unclear.
RCT conducted in US university medical center prenatal clinics. | Overall group (reported as mean DR in the previous month): mean (SD) 9 (20.48) | Interview began with ascertainment of participant's knowledge about effects of drinking during pregnancy. | ANCOVA results for treatment group differences: | Follow-up losses were 19%.
Standard Drink (DR) = standard ethanol content unit (SEC) = 0.5 oz (15 ml) ETOH | Peak blood alcohol concentration (BAC), considered the best indicator of fetal exposure, estimated by self-report | Included feedback on potential harm to fetus caused by the participant's drinking. | Total drinks: F=0.01, 1/31 df, p=0.94 | Replacement of missing values is NR.
| Inc/Exc Criteria: | Goal was to increase participant's perception of health risks drinking posed to the fetus while supporting self-efficacy to reduce or quit drinking. | Days abstinent: F=1.25, 1/31 df, p=0.27 | Patients and outcomes blinded: Satisfactory.
| Inclusion: Pregnant females consuming ≥ 1 drink in the previous month. | Participants advised that quitting drinking at any time during pregnancy could lead to better outcomes. No explicit description of assistance toward reaching goal of abstention. | Peak BAC: interaction between treatment group and peak BAC at baseline - among women with highest baseline BAC's, intervention reduced peak BAC at followup relative to controls. | Group comparisons at baseline were not reported.
| Exclusion: NR | Conducted using an empathic, client-centered but directive style. | Estimate effect sizes (theta): | Clearly delivered intervention:
| % Female: 100% | Although tailoring not mentioned specifically, interview began with determining each participant's level of knowledge about alcohol and pregnancy. | Change in consumption: | Yes.
| % Minority: 62% | Intervention delivery not reported. | IG 0.46
| Motivation Composite: Measured in the IG only using SOCRATES before and after intervention. | No further followup. | CG 0.40
| | CG (n=22) mailed a letter post-assessment informing them about risks of drinking during pregnancy and referring them to their health care providers. | Change in BAC:
| | Harms not reported. | IG 0.77
| | | CG 0.46
| | | Change in abstinent days:
| | | IG 0.69
| | | CG 0.20
| | | Proportion benefiting:
| | | NR

Table 10 Excluded Adult Intervention Studies (Includes those excluded for quality and other reasons)

Study Identification | Population/Setting | Reason for Exclusion
Romelsjo et al. Brit J of Addiction, 1989 ^135^ | Adults, 18–64 | POOR QUALITY: Randomization process was not simple, but quota sample, stratified on GP and then on practice. Masking of GP not assured. Significant post-randomization exclusion (151/258).
| Sweden | Inclusion criteria not adequately applied, resulting in missing of the majority of eligibles based on drinking (and not laboratory levels). Non-comparable groups assembled at baseline with respect to alcohol consumption & problems and no adjustment for differences. Attrition rate relatively low (11/83) and non-differential. Does not appear to be intent-to-treat analysis, as some cases followed up were not included in reported analyses. No statistical testing of results reported.
Oliansky, et.al. Substance Abuse, 1997 ^136^ | Adults, 18–55 | POOR QUALITY: Three different populations in three different clinics were “randomly” assigned to intervention vs. control conditions. In two clinics, random assignment was based on odd/even medical record numbers. In the third, the randomization method was not described. Comparability of intervention and control groups at baseline wasn't reported. The intervention was not clearly defined.
| Adolescents 12–18 | The measures used to determine eligibility for the study and to measure outcomes (Substance Use Screening Instrument-SUSI) is a novel instrument developed for this project. It is reported as based on AUDIT and CAGE, but the actual items included in SUSI aren't provided. Loss to follow-up was up to 39% in one clinic and was greater in intervention conditions if there were equal numbers in intervention and control groups initially (can't be sure from report). Maintenance of comparable groups not reported. Outcomes were reported for all substances combined (alcohol, tobacco and other drugs of abuse).
| Female adults 18–55
| United States
Tomson, et.al. Scand J Prim Health Care,1998 ^137^ | Adults, 25–54 | POOR QUALITY: Unequal randomization results (intervention n=100, control n=122) without rationale. Comparability of intervention and control groups at baseline not assured as control group not assessed for CAGE or alcohol consumption at baseline. Change in CAGE and alcohol consumption not measured in control group, therefore measures not equal. Possible contamination of control condition by receipt of GP intervention. High attrition rates (50–62%), with loss to follow up greater in the intervention condition. Analyses don't account for baseline differences and no test of between-group differences for primary outcomes (except GGT).
| Sweden
Cordoba, et.al. Family Practice, 1998 ^138^ | Adult males, 14–50 | POOR QUALITY: 270/546 excluded from analysis (49%) due to loss to follow up or noncompliance with protocol (60/270). Therefore, not intent-to-treat analysis. Unit of randomization was the primary care practice, unit of analysis was the patient. Other problems not listed as analytic approach represents a fatal flaw.
| Spain
Dimeff, 1997 (PhD dissertation) | College student health center patients | POOR QUALITY: Post randomization attrition from both groups. Early dropouts from intervention group excluded from further analysis (did not use intent-to-treat design). Small sample (N=36), short followup (30 days), very low intensity computer-based intervention.
Dimeff & McNeely Cognitive & Behavioral Practice, 2000 ^139^ | United States
Blair, 2000 ^140^ (PhD dissertation) | Undergraduate college students | POOR QUALITY: Non-randomized allocation to treatment and control; subjects were “assigned”.
| United States | POOR QUALITY: Unequal assignment to treatment (n=74) vs. control (n=103) from using pilot study participants to increase sample size. Assembly of comparable groups at baseline was not reported. Loss to follow up was significant at 4-week follow up (20/74 in treatment and 29/103 in controls). Outcomes in pretest-post-test design could not be matched between individuals at baseline and follow up.
McIntosh, 1997 ^141^ | United States | POOR QUALITY: Unclear allocation concealment with baseline non-comparability between comparison group numbers and probably differences in alcohol quantity frequency measures, particularly among women. Inadequate power for analyses including all participants at baseline, thus results reported by gender subgroups must be underpowered.
Burton, 1995 ^142^ | United States | POOR QUALITY: Single alcohol outcome measure not clearly defined; presumed measure (change in lifetime CAGE responses) is insensitive and lacks content, concurrent, and predictive validity for improvement among problem drinkers addressed as part of this population-based multifactorial risk factor intervention.
Aalto, 2000 ^143^ | Finland | POOR QUALITY: Inadequate allocation concealment with intervening physician “drawing a card” to assign randomization condition to patients during intervention. 34% overall loss to follow-up with large differences between groups that could affect results even though not statistically significant possibly due to small sample sizes. No replacement of missing values in analyses. Unclear blinding of participants or outcome assessors and unclear intervention delivery.
Aalto, 2001 ^144^ | Finland | POOR QUALITY: Inadequate allocation concealment with intervening physician “drawing a card” to assign randomization condition to patients during intervention. Unequal n's in comparison groups at baseline. 32% overall loss to follow-up with large differences between groups that could affect results even though not statistically significant possibly due to small sample sizes. No replacement of missing values in analyses. Unclear blinding of participants or outcome assessors and unclear intervention delivery.
Logsdon, 1989 ^145^ | United States | POOR QUALITY: Use of single alcohol outcome measure without definition of how measured at baseline and without definition of how change was quantified. Otherwise well-conducted feasibility CCT of multifactorial preventive intervention in primary care.
Persson & Magnuson, 1989 ^146^ | Sweden | POOR QUALITY: Alcohol consumption measures reported for intervention groups but not controls. Unclear allocation concealment and 31% overall attrition rate. Unclear blinding of participants or outcome assessors.
Heather, 1987 ^147^ | Scotland | POOR QUALITY: Less than half of intended intervention participants received the full intervention due to implementation design difficulties. Post-randomization exclusions of participants with numbers not reported.
Israel, 1996 ^148^ | Canada | POOR QUALITY: Loss to followup 30%, with no adjustment for missing data at followup. Baseline comparison of study group composition unclear.
Waterson, 1990 ^149^ | England | POOR QUALITY: Concealment of allocation a concern, as clinics were assigned to conditions non-randomly. High and differential attrition between groups (41% and 50% to first followup assessment, 26% and 66% at second followup assessment), which analyses do not address, reduce interpretability of findings.
Kristenson, 1983 ^115^ | Sweden | POOR QUALITY: High attrition at first followup (2yr): 41% in intervention group, 27% in control group, unclear blinding at followup assessment.
Heather, 1987 ^198^ | Scotland | EXCLUDED SETTING AND POOR QUALITY: Media-recruited problem drinkers received two levels of self help intervention. Attrition rate 55% with differences between groups and no replacement of missing values in analysis.
Antti-Poika, 1988 ^150^ | Finland | EXCLUDED HEALTH CARE SETTING: Nurse and M.D. counseling of hospitalized injured male patients who screened heavy drinkers or alcoholics was evaluated in randomly assigned intervention vs. controls.
Blondell, 2001 ^151^ | United States | EXCLUDED HEALTH CARE SETTING: Brief physician intervention with and without peer intervention was compared to usual care among nonrandomized patients hospitalized for alcohol-related injuries.
Elvy, 1988 ^152^ | New Zealand | EXCLUDED HEALTH CARE SETTING: Evaluation of inpatient referral of hospitalized problem drinkers.
Forsberg, 2000 ^153^ | Sweden | EXCLUDED HEALTH CARE SETTING: Randomized comparison of brief vs extensive alcohol intervention in an emergency surgical ward by surgical staff.
Gentilello, 1997 ^159^ | United States | EXCLUDED HEALTH CARE SETTING: Randomized comparison of subsequent alcohol consumption and emergency department visits among alcohol-affected patients receiving an onsite intervention in a trauma center vs. controls.
Gentilello, 1999 ^154^ | United States | EXCLUDED HEALTH CARE SETTING: Randomized comparison of reinjury rates among alcohol-affected patients in a level 1 trauma center receiving brief intervention vs. controls.
Heather & Rollnick, 1996 ^155^ | Australia | EXCLUDED HEALTH CARE SETTING: Controlled trial of brief moivational interviewing, skills-based counseling, or usual care on alcohol consumption after discharge among hospitalized heavy male drinkers.
Monti, 1999 ^156^ | United States | EXCLUDED HEALTH CARE SETTING: Randomized comparison of brief motivational interviewing or usual care on alcohol-related consequences among adolescents seen in the emergency department.
Watson, 1999 ^157^ | Scotland | EXCLUDED HEALTH CARE SETTING: Comparison of three brief nursing interventions to reduce alcohol consumption on potential problem drinkers in general hospital wards.
Welte, 1998 ^158^ | United States | EXCLUDED HEALTH CARE SETTING: Comparison of risk reduction intervention with treatment referral or usual care among general hospital patients at risk for (or with) alcohol dependence.

Figure 2. Literature Search and Retrieval Results for Intervention Trials

Key questions 3 and 6. We conducted searches in MEDLINE and PsychInfo from 1994 through April 2002 combining the terms described in Table 6 of the Appendix, with “adverse effects of screening” and “adverse effects of counseling” to identify any literature on the harms of alcohol screening, screening-related assessment, or intervention, but none was found.

## Inclusion and Exclusion Criteria

Figure 3 of the Appendix, includes a list of the eligibility criteria used to select articles for inclusion in evidence tables. To be eligible, studies had to be conducted in a primary care setting, as defined in a recent Institute of Medicine report. ^103^ Other clinical settings, such as emergency departments and hospitals, were excluded from this review to maximize the applicability of the review findings to primary care. Excluded studies are listed in Table 10 of the Appendix. Titles and abstracts were reviewed for eligibility, and full-text articles of potentially eligible studies were re-assessed using the same criteria. Included articles were re-reviewed by a second investigator to confirm eligibility and quality ratings. Studies receiving a rating of “poor-quality” according to the USPSTF criteria ^100^ were excluded from the review (see Appendix: Table 10).

Figure 3. Abstract and Article Review Process for Problem Drinking Interventions

## Data Extraction, Reliability, and Validity Assessments

All studies were abstracted by one of the study investigators into standardized data-abstraction forms developed for this review. Data-abstraction forms addressed three issues: 1) study recruitment, randomization, and attrition (adapted from CONSORT ^104^ ), 2) study design, conduct, and results, and 3) quality (see Appendix: Forms 1–4). A separate audit of study outcomes was conducted by one of 2 research assistants, and all items abstracted into final evidence tables were double-checked by a second reviewer. A second investigator also conducted a quality review audit of each study, emphasizing the key aspects of quality in this literature (allocation concealment, attrition and replacement of missing values, baseline and final comparability of groups, adequate intervention delivery, and masking of patients and outcome assessment). The final quality rating for each study (Good, Fair, Poor) reported in the evidence tables was based on the USPSTF criteria ^100^ and assigned by consensus of the investigator team.

## Study Characteristics Extracted During Review

Study Identification. We abstracted author, year published, type of trial, setting, and definition of a standard drink used in the study.

Study Participants. We abstracted the total number randomized to the study, the proportion of female and non-White participants, participants' baseline alcohol consumption, the proportion that was alcohol dependent, and the proportion that was motivated, help-seeking, or thought they had a problem with alcohol.

Intervention and Control Conditions. Information abstracted included whether alcohol screening or screening-related assessment was masked within a more general lifestyle assessment; intervention and control protocols; whether the intervention involved personal contact; the intensity of personal contact (number of contacts and total contact minutes); whether intervention delivery was measured and found to be above 75%; all provider types involved; the use of usual care, other clinical or research personnel, and intervention elements (advice, feedback, goal setting, assistance, followup, matching, and tailoring); and whether harms were reported.

We abstracted other intervention components besides intensity cited as important elements in brief interventions. ^40,^ ^55,^ ^64,^ ^105^ These included:

1 advice to reduce current drinking and/or about guidelines for low-risk use;
2 feedback about current drinking patterns, problem indicators (such as laboratory results), and/or medical consequences of current use patterns;
3 explicit goal-setting, usually for moderation and not abstinence;
4 assistance in achieving the goal, including providing a menu of options for change, helping patients develop skills for managing high-risk drinking situations (e.g., recognizing antecedents, planning ahead, pacing drinking), coping with problems without drinking, and providing self-help materials.
5 providing followup in the form of telephone calls, repeat visits, and/or repeat monitoring of lab test, physical examinations, etc.

These components map to the 5As (Assess, Advise, Agree, Assist, Arrange/Adapt) adopted by the USPSTF for reporting the results of behavioral counseling interventions, ^56^ which are described in Discussion. We also evaluated the presence or absence of described tailoring in the intervention.

Outcomes. A large variety of alcohol use variables and measures reflecting different definitions of problematic use were reported in different studies (for more information, see Table 1). To facilitate comparison between studies, we chose 3 primary alcohol use outcome categories commonly reported in epidemiologic and intervention literature: average consumption, binge use, and safe/moderate/recommended use. We preferentially report the outcome measures as reported by the study authors, or where necessary, we used established methods to recalculate reported study data into more comparable outcome measures ^106^ . For average use outcomes, we abstracted the absolute follow-up levels (or change from baseline to 6–12 months' follow-up) in mean drinks per week for each arm of the study. If these were not available, we abstracted any other recent average consumption measures and converted them to mean drinks per week where possible. For binge use, we abstracted the percentage or proportion bingeing or not bingeing, or the reduction in either of these measures. We then calculated the converse (1 minus reported percentage), where necessary, to convert all measures to percentage not bingeing. Studies varied in their definition of safe, moderate, or recommended use of alcohol (based on attaining each study's recommended limits on average consumption and/or binge use). To consider what percentage of study participants attained these recommendations, we created or adapted the within-study definition that best fit each study's intervention rationale and focus. For each study, we then abstracted or calculated from reported data the percentage achieving “recommended” levels or patterns of alcohol use by group. For all the outcome categories, we recorded outcomes for all groups when studies had more than 1 intervention or control group. Similarly, we abstracted outcomes by gender where possible. We also examined health outcomes in the original intervention study (or subsequent reports) when available.

Generalizability. We recorded study recruitment (including whether patients were or were not primarily opportunistically recruited as part of routine care), provider support and training, use of research vs. clinical personnel, and use of incentives for providers or patients to participate in the study.

Data Synthesis. To synthesize the results of the studies, we qualitatively compared results for the 3 selected alcohol use outcomes reported in the evidence tables and created 5 graphical outcome summaries (Figures 4–8). We examined the consistency and direction of the evidence for the effect of brief interventions on net (i.e., intervention minus control) change in mean drinks/week (n=8), on net percentage point decrease in average consumption from baseline (n=8), on the proportion not reporting binge drinking at follow-up (n=7), and on the proportion of subjects achieving recommended drinking levels/patterns after brief interventions (n=10). To calculate the net reduction in mean drinks/week, we used reported mean differences in between-group changes from baseline to follow-up or calculated group means, changes in group means, and between-group net mean differences. To calculate the percentage point reduction in average consumption from baseline for each group, we divided the reduction in mean drinks/week by the baseline mean drinks/week and multiplied by 100. We then subtracted the percentage reduction in the control group from the percentage reduction in the intervention group to obtain the net percentage point reduction in mean drinks per week. For the remaining 2 outcomes, we used directly reported percentages or proportions of those in intervention and control groups 1) not bingeing and 2) achieving recommended drinking levels or patterns. Where necessary, we used the converse (1 - proportion) to convert data for comparability. If these latter 2 outcomes were not directly reported but other relevant data were available, we calculated the relevant percentages from the number reported as meeting the criterion at follow-up divided by the number randomized to that group. Where available, outcomes were reported separately by gender. We examined results for all intervention arms (n=15) for which these outcomes were reported or could be calculated.

Figure 4. Net reduction in mean drinks per week^*^ † ‡ * To calculate the net reduction in mean drinks/week, we used reported mean differences in between-group changes from baseline to follow-up or calculated group means, changes in group means, and between-group net mean differences. † ^†^ n = the number in the intervention and control groups for this comparison. ^‡^ Studies in italics had statistically significant differences between intervention and control groups, p<.05.

Figure 8. Percent Achieving Recommended Drinking Levels/Patterns at Followup (By Gender)

Evidence Synthesis. We used the USPSTF approach to grade the overall quality of evidence for each key question. ^100^