# Background

Alcohol misuse is associated with numerous health and social problems, and with over 100,000 preventable deaths per year. ^1^ In the United States, the estimated economic cost of alcohol abuse in 1998 was $184.6 billion (about $638 per man, woman, and child. ^2^ Even considering possible health benefits from moderate use, alcohol use results in more years of life lost than gained overall, largely because associated harms occur at younger ages relative to potential benefits ^2^ Also, alcohol misuse probably has a greater effect on nonfatal than fatal health consequences. In established market economies, alcohol use has a relatively greater effect on disability-adjusted life years (15.6% of all years lost due to disability) compared with mortality (5.1% of potential life years lost). ^2^ Persons who misuse, abuse, or are dependent on alcohol have elevated risks for a host of health problems, including chronic diseases and injuries. ^2^ – ^5^ For example, higher levels of alcohol consumption have been linked to increased risk of liver cirrhosis, diseases of the central nervous system, hypertension, and cancers of the head and neck, digestive tract, liver, and breast. ^2,^ ^4,^ ^6,^ ^7^ Risk of injury is elevated among those who drink alcohol, and generally increases with greater quantities of alcohol consumed. ^2^ Consumption of alcohol also increases the risk of violence and escalation of aggressive behavior, and violence-related trauma is strongly linked to alcohol use. ^2^

Special risks are associated with alcohol use by pregnant women. Among pregnant women, for example, moderate drinking has been linked to an increased risk of spontaneous abortion. ^8^ Additionally, heavy maternal alcohol consumption during pregnancy can lead to a range of physical and cognitive birth defects, including the fetal alcohol syndrome (FAS), a serious developmental disorder with characteristic facial abnormalities, growth retardation, and reductions in general intellectual functioning and academic skills, cognitive and motor functioning, and social functioning. ^2^

Despite the risks associated with alcohol, most individuals who consume alcohol do so without encountering adverse consequences. Moreover, light or moderate alcohol consumption may be beneficial in some groups; in many population-based longitudinal studies, light-to-moderate drinkers have lower mortality risk than either abstainers or heavier drinkers. ^9^ – ^22^ A recent analysis of US National Health Survey data found that protective effects on mortality were most pronounced for men who drank fewer than 2 drinks per day and for women who drank fewer than 1 drink per day. ^23^ The apparent benefit of light/moderate drinking is usually attributed to reduced risk of coronary heart disease, ^2,^ ^5,^ ^7^ and may, therefore, be limited to populations with at least moderate coronary heart disease risk. Additionally, an epidemiologic analysis from England using published population-based data and relative risks suggests that a net mortality benefit from alcohol consumption occurs only for men over aged 55 and women over aged 65. ^24^ High levels of alcohol intake (beginning at about 4–5 drinks/day for women and 12–13 drinks/day for men) appear to be related to increased risk of coronary heart disease in men and in women. ^5^

Moderate drinking has been associated with other positive health outcomes, ^25^ including subjective good health (among non-smokers), ^26^ reduced sickness absence, ^27^ better physical functioning (among older women), ^28^ reduced susceptibility to the common cold, ^29^ and improved disease markers in diabetic women. ^2,^ ^30^

## Health Risks Associated with Alcohol Consumption

Because alcohol use is not always harmful, interventions to reduce drinking need to be directed toward individuals who have a high risk of having complications. Unfortunately, singling out specific individual consumption measures that account for the observed relationship between alcohol consumption and health outcomes is difficult or impossible. ^2^ In US and Canadian studies, however, epidemiologic evidence consistently supports the associations between 2 specific alcohol use measures—average consumption of alcohol and amounts consumed on specific occasions—and negative health consequences. ^2,^ ^31^ – ^36^ Weekly consumption in standard drinks has been related primarily to long-term, chronic health effects, while characteristics such as heavy episodic drinking (“binge use”), drinking to intoxication, or drinking in association with other activities such as driving have been related primarily to acute injury risks or alcohol-related life problems. ^31^ In the United States, a standard drink is considered to be 0.5 ounces (oz.) or 12–15 grams of alcohol, which is the amount contained in 12 oz. of beer, 5 oz. of wine, or 1.5 oz. of 80-proof distilled spirits. ^2,^ ^3^

Average weekly alcohol consumed. For short- and long-term health risks, men averaging up to 14 standard drinks per week are at lower risk than abstainers, while women averaging 9 standard drinks or less per week are at lower risk than abstainers. ^31^ Above these levels, risk increases in a relatively linear fashion, the slope of which varies by health risk considered. ^31^ The risk for both treated and untreated injuries does not increase in current drinkers until intake averages 1 or more drink per day. A meta-analysis of all-cause mortality and usual alcohol consumption reported significantly increased mortality, relative to that of non-drinkers, at 4 drinks per day among men and 2 drinks per day among women. ^32^

Heavy Episodic Drinking. Drinking patterns may predict alcohol-related problems better than average consumption. ^33^ This pattern is consistent with the “prevention paradox,” ^34^ whereby the largest number of people reporting alcohol problems is found in categories of low-to-moderate average consumption. In general population studies, consuming higher amounts of alcohol on single occasions (heavy episodic or binge use) has a stronger relationship than average weekly consumption to acute alcohol-related consequences, such as injuries or self-identified problems. ^31^ Risks for younger people are particularly related to heavy episodic drinking patterns (binge use), and to engaging in behaviors during or after drinking that increase potential for injury, especially driving while impaired.

A higher injury risk for heavy episodic drinkers (those consuming 5 or more drinks on one day) is seen even with low-levels of such drinking and increases linearly as frequencies of such drinking increase up to 3–6 times in the previous year. These higher injury rates are maintained when individuals drink heavily as seldom as 3–6 times per year to as frequently as 3–4 times per week, compared with others. ^35^ At these levels of heavy episodic drinking, reported injury rates are at least 50% higher than non-bingers' injury rates (10–15%). At average consumption levels up to 2–3 drinks per day, rates of injury are 50–150% higher in those who ever consumed 5 or more drinks on one day compared to those who never did. Overall, fatal injury risk nearly doubles among heavy episodic drinkers relative to lighter drinkers. ^36^ Females appeared to be at lower risk for injury than men at almost all consumption and intake/occasion categories. ^35^ It is possible that women are less likely to consume alcohol and perform risky activities, showing the importance of the association of drinking levels and behavior, particularly for short-term risk.

The assumption underlying brief motivational and educational interventions in primary care is that reducing overall alcohol consumption or improving drinking patterns toward safer use (i.e., reduced binge use, not drinking before driving) will lower the risk of medical, social, and psychological problems. ^37^ There is little direct experimental or even indirect epidemiologic evidence to support this assumption, since most cross-sectional and cohort studies relate health outcome to existing drinking behaviors, rather than to changes in drinking behaviors. In one cohort study ^38^ of self-selected problem drinkers interested in cutting down (144 males and 91 females), those who reduced their usage over time reported fewer alcohol-related problems. At 12 months follow-up, 55% of the drinkers were problem-free (n=128). The problem-free group reported fewer mean drinks/week (12, 95% C.I. 10–14) than the continuing problem group (n=107)(mean drinks/week 24, 95% C.I., 21,28).

## Guidelines for “Low-risk” Alcohol Consumption

Several national and international agencies have established guidelines for levels of alcohol consumption that are considered to be “safer” or “low-risk” or “moderate.” These guidelines do not apply to persons (e.g. adolescents, pregnant women, those with alcohol dependence) or circumstances (e.g., driving) when no alcohol consumption is considered safe. Safe daily alcohol intake recommendations take into consideration both short-term and long-term health risks. ^31^ Most of these guidelines are based on epidemiological evidence accumulated by the early 1990s, in which self-reported usual alcohol consumption patterns were linked to incidence rates of various diseases, to mortality, and to other health outcomes. In the United States, the guideline for “moderate” drinking limits proposed by the National Institute on Alcoholism and Alcohol Abuse (NIAAA) is gender- and age-specific: Maximum recommended consumption is ≤1 standard drink per day for adult women and for anyone over age 65, and ≤2 standard drinks per day for adult men (see Appendix, Table 1). ^39,^ ^40^ In addition, abstinence from alcohol is recommended for women who are pregnant or considering pregnancy, for persons taking medications that interact with alcohol, for those who are alcohol dependent, and for those with a medical condition for which alcohol is contraindicated. ^39,^ ^40^ The lower limits for women and older adults are based on differences in metabolism of alcohol and proportions of total body water that combine to increase intoxication levels associated with equivalent amounts of alcohol in women and the elderly relative to younger men. ^39^

Table 1 Definitions of drinking disorders, patterns, and categories

Alcohol Consumption Category | Terms | Definitions | Prevalence/population
“Excessive” | Alcohol use disorders: | Dependence: 3 or more of the following during a 1-year period:; 1 tolerance;; 2 withdrawal;; 3 intake larger amounts than intended;; 4 persistent desire or unsuccessful efforts to cut down;; 5 “a great deal” of time spent obtaining, using, or recovering from use of alcohol;; 6 social, occupational, or recreational activities reduced because of alcohol use;; 7 use continues despite knowledge of related problems. Specifier: Physiological dependence if either item 1 or 2 is present. | 7.4% of general population meet criteria for abuse/alcoholism ^2^
| Alcohol dependence | Abuse: 1 or more of the following during a 1-year period:; 1 recurrent use results in failure to fulfill role obligations at work, school, or home;; 2 recurrent use in physically hazardous situations (e.g., driving a motor vehicle);; 3 recurrent legal problems related to use;; 4 continued use despite related persistent or recurrent social or interpersonal problems. ^41^ | 10% of current drinkers meet diagnostic criteria for dependence and another 7% for abuse ^49^
| Alcohol abuse | Alcoholism: “...is a primary, chronic disease with genetic, psychosocial, and environmental factors influencing its development and manifestations. The disease is often progressive and fatal. It is characterized by impaired control over drinking, preoccupation with the drug alcohol, use of alcohol despite adverse consequences, and distortions in thinking, most notably denial. Each of these symptoms may be continuous or periodic”. ^42^
| Alcoholism | Chronic Alcoholics: “...individuals whose life is centered around procuring and consuming alcohol and who, upon stopping drinking, suffer severe withdrawal symptoms.” ^44^
| Chronic alcoholism | Harmful drinking: >5 drinks/day (NHMRC [Aust.] recommendations, cited in Holman, et al. ^32^ ); “exhibit physical, social, or psychological harm, but may not meet criteria for dependence” ^44^
| Harmful drinking
“At-risk” | Problem drinking | Problem drinkers: “typically have either experienced negative consequences of their drinking or drink in ways that place them at risk of such consequences; however, they usually do not drink steadily, do not show major withdrawal symptoms when they stop drinking, and sometimes drink with control, and their lives do not revolve around drinking” ^43^ | 55% of current adult drinkers binged (5 or more drinks on an occasion) in last year; 12% binged weekly or more; 16% binged in past month. ^45^
| Hazardous drinking | Hazardous drinking (a): AUDIT score >=8 ^46^ | 32% of HS seniors and 39% of college students binged in last 2 weeks; 20% of current drinkers average over 2 drinks/day ^45^
| At-risk or risky drinking | Hazardous drinking (b): 3–4.9 drinks/day (NHMRC [Aust.] recommendations, cited in Holman, et al. ^32^ ) | Among pregnant women, 15–44, 15.3% used alcohol & 2.9% binged ^45^
| Binge drinking | At-risk drinking:; 1 >7 drinks/week for women, >14 drinks/week for men; or binge drinking (drinks per occasion >3 for women and > 4 for men) ^38,^ ^40^; 2 >14 drinks/week for women, >21 drinks/week for men; or binge drinking (WHO guideline, in Saunders et al. ^46^ ); “at risk from exceeding daily, weekly, or per occasion thresholds” ^44^
| Heavy or heavier drinking | Binge drinking: 6 or more drinks/occasion; ^47^ 5 or more drinks/occasion (BRFSS, cited in Holtzman et al. ^48^ ); 5 or more drinks/occasion in last 30 days ^49^
| Heavy or heavier episodic drinking | Heavier drinking: >2 drinks/day ^50^
| | Heavier episodic drinking: >4 drinks/occasion for men, >3 drinks/occasion for women ^39,^ ^40^
“Responsible” or “appropriate” | Light or lighter drinking | Responsible drinking: >0 to 2.9 drinks/day (NHMRC [Aust.] recommendations, cited in Holman, et al. ^32^ ) | 72% of female and 74% of male current drinkers aged 21 and older exceed NIAAA moderate drinking guidelines. ^45^
| Moderate drinking | Light drinking: 0.01 to 0.21 fl oz alcohol/day (1 to 13 drinks/month) ^50,^ ^51^
| Safe drinking levels | Moderate drinking (a): Average consumption of ≤1 standard drink/day for women and for anyone over age 65; ≤2 standard drinks/day for men. ^39^
| Low risk drinking guidelines | Moderate drinking (b): ≤ 3 drinks/day and ≤12 drinks/week for women; ≤4 drinks/day and ≤16 drinks/week for men ^38^
| | Moderate drinking (c): 0.22 to 1.00 fl oz alcohol/day (4 to 14 drinks/week ^50,^ ^51^
| | Low risk drinking: <2 drinks/day (Canadian Medical Association guideline, cited in Ashley et al ^52^ )
“Current Use” | current use | Current drinkers—at least 12 drinks in the preceding year; ^2^ at least 1 drink in last 30 days ^49^ | Current drinkers—44% of Americans 18 and older; ^45^
| | Adolescent/young adult use—used in last month, ever use. | 12^th^ grade ever use-81%; Last month use-20% ^45^ (ages 12–17); 59% (ages 18–25) ^45^

Note: In the U.S., a standard “drink” is typically defined as a half-ounce of alcohol, roughly the amount in 12-ounces of beer, 5-ounces of wine, or 1.5 ounces of distilled spirits. ^41^ Standard drink units in other countries are reported in a variety of volume and weight measures, including imperial ounces, grams, and milliliters (see Miller et al ^197^ for conversion factors).

Establishing general consumption guidelines is made more difficult because alcohol has complex associations with different diseases, because both short-term and long-term consequences must be considered, because similar average consumption levels can reflect very different drinking patterns (e.g., combinations of frequency and intensity of drinking per occasion), and because excessive or risky drinking has negative outcomes for the persons themselves and for others (e.g., through auto crashes). Given the substantial individual variation in reaction to even low doses of alcohol, and the lack of controlled trial evidence of efficacy, no guidelines advise initiating moderate drinking among non-drinkers as a means of potentially reducing the risk of coronary heart disease (CHD).

Independent researchers in at least 2 countries (Canada and Australia) ^31,^ ^32^ have examined whether drinking guidelines similar to those suggested by NIAAA predict negative health outcomes. With regard to all-cause mortality, Holman et al. ^32^ validated the Australian National Health and Medical Research Council's guidelines for “responsible” drinking (from 0–2.9 drinks per day, with a standard drink defined as containing 10g of alcohol), showing in a meta-analysis that persons whose usual consumption was within these parameters had mortality risks lower than or equal to those of non-drinkers. Risky/harmful drinkers had excess mortality risks compared with abstainers or responsible drinkers. These results also confirmed the validity of sex-specific guidelines, with women experiencing the greatest protective effect at fewer than 1 drink per day, and men at 1–2 drinks per day. Note that because of different standard drink definitions, 2.9 Australian drinks would equal about 2.0 U.S. drinks.

## Screening, Counseling, and Treatment Interventions

There is little consistency in terms and definitions that have been applied to describe drinkers across the range of problematic alcohol use patterns. We have summarized key terms and definitions proposed by various institutions and experts in Table 1. ^2,^ ^32,^ ^38,^ ^40^ – ^52^ For the purposes of this review we have chosen the following definitions: ^44^ 1) Risky or hazardous drinkers: those at risk from exceeding daily, weekly, or per occasion thresholds (other terms further distinguish risky/harmful users who exceed longer term thresholds, e.g., high average or heavy users, from heavy occasional or binge users who exceed per-occasion thresholds); 2) Harmful drinkers: those that exhibit physical, social, or psychological harm, without meeting criteria for dependence; 3) Alcohol abuse/dependent drinkers: those that continue to use alcohol despite significant negative physical, psychological, and social consequences. This latter category generally meets DSM IV diagnostic criteria. ^41^

Patients with a range of alcohol-related risks and problems are commonly seen by the primary care clinician, with about 20% of primary care patients in Wisconsin meeting NIAAA criteria for risky drinking. ^47^ A range of risky drinkers (4–29%) have been found across multiple primary care populations, with prevalence estimates of .3–10% for harmful drinkers, and of 2–9% for alcohol dependence. ^53^ Alcohol use disorder rates among medical outpatients are similar to those seen in the general population, and are generally higher in males and younger people of all races/ethnicities. ^45,^ ^53^ Physicians who provide ongoing care can assist patients who have current problems, or who are at risk for problems, through effective identification (screening and screening-related assessment), office-based interventions and referrals to specialty services as needed, ^54^ as recommended for primary care physicians by the National Institute on Alcoholism and Alcohol Abuse. ^40^ Screening and screening -related assessment procedures distinguish abstainers and low-risk users from those showing at-risk, problem, or dependent alcohol use. ^55^ Those with alcohol dependence or severe problem use are advised to abstain and referred for specialty treatment. Those with risky or moderate harmful use can receive brief intervention as part of routine care. Brief interventions are defined as “time-limited, patient-centered counseling strategies that focus on changing behavior,” and it is noted that “these counseling strategies are widely used by physicians and other health care professionals for a number of behaviors.” ^55^

Brief alcohol interventions in primary care are behavioral counseling activities delivered by clinicians and related healthcare staff to assist patients in reducing or changing risky or harmful patterns of use to those associated with reduced risk and improved health outcomes. ^56^ The aim is to intervene early, before or soon after the onset of alcohol-related problems or consequences. ^57^ Brief alcohol-related behavioral counseling interventions occur entirely or in part in routine primary care and use instructional and motivational methods to actively engage patients in the self-management practices needed to change their alcohol use. ^56,^ ^57^ These interventions range from very brief interventions within a primary care visit to multi-contact interventions involving multiple, often more lengthy, visits and non-visit contacts over an extended period. For the purposes of this review, we have adapted terminology that combines various common definitions to consistently describe the intensity of these interventions (see Appendix, Table 2). ^37,^ ^57^ – ^59^ These definitions specify 2 major intensity dimensions: duration of initial contact, and presence or absence of followup contacts.

Table 2 Intensity of intervention definitions

INTERVENTION TYPES | STUDY OR INTERVENTION CONDITION* | INITIAL INTERVENTION SESSION | FOLLOW-UP CONTACTS
VERY BRIEF | - Richmond, 1995 ^117^ (IG2); - WHO 1996 ^119^ (IG1) | - Up to 5 minutes | - No follow-up contacts
BRIEF | - Anderson & Scott ^116^ 1992; - Maisto 2001 ^122^ (IG1); - Nilssen 1991 ^125^ (IG1); - Scott & Anderson 1990 ^118^; - Senft 1997 ^124^; - WHO 1996 ^119^ (IG2) | - Up to 15 minutes | - No follow-up contacts
BRIEF, MULTICONTACT | - Curry 2002 ^126^; - Fleming 1997 ^111^; - Fleming 1999 ^120^; - Maisto 2001 ^122^ (IG2)**; - Nilssen 1991 ^125^ (IG2); - Ockene 1999 ^127^; - Wallace 1988 ^128^ | - Up to 15 minutes | - Multiple follow-up contacts

* Includes 15 intervention conditions from 12 studies. The multiple intervention groups from Maisto 2001, ^122^ Nilssen 1991, ^125^ and WHO 1996 ^119^ are designated by IG1, IG2, etc., and are described in the evidence table for adult interventions (Table 8).

** This intervention group from Maisto 2001 ^122^ had a 30–45 minute initial session plus 2 15–20 minute booster sessions.

Our review focused on the general category of “early intervention” for high-risk/early harmful drinkers. Specialized treatment programs ^37^ for more severe harmful and dependent drinkers that treat medical complications of drinking and assist in social and psychological rehabilitation of the drinker are briefly summarized next. Mutual help groups ^37^ that facilitate long-term rehabilitation through continuing care and support are outside the scope of this review.

A recent review of 361 quality-rated controlled studies of treatments for alcohol dependence or abuse ^60^ concluded that several treatments are effective, but that outcomes vary depending on the type of treatment. The most effective psychosocial treatments in treatment-seeking populations were brief interventions (advice-giving, usually with additional procedures completed in 1–2 sessions), social skills training, and community reinforcement approaches (functional analysis of drinking behavior with a specified menu of skills-training procedures, used to create an individualized treatment program). Behavior contracting, behavioral marital therapy, case management, and cognitive therapy were also effective treatments, although less so than those previously listed.

The reviewers also found strong support for the efficacy of pharmacotherapies—both opiate antagonists (naltrexone, nalmefene) and acamprosate. ^60^ Disulfiram ranked as the 10^th^ most effective treatment after all aforementioned psychosocial and pharmacotherapeutic treatments. Miller and Wilbourne's ^60^ results are consistent with a recent evidence report on pharmacotherapy for alcohol dependence. ^61^ Of the treatments covered in the Miller and Wilbourne review, most ineffective were those attempting to foster insight into the nature and causes of alcoholism, to educate regarding alcoholism, or to shock or confront patients about their alcoholism.

Clinical referral to treatment programs for alcohol use disorders provides patients with information about available services and important linkages to those services. Patients receiving referrals based on positive screening results appear more likely to accept appointments for alcohol-related counseling than those receiving usual care. ^62^ Additionally, patients with alcohol use disorders who achieve long-term abstinence are likely to have reduced risk of mortality. ^63^

## Prior USPSTF Recommendations

In 1996, the USPSTF recommended screening to detect problem drinking in all adults and adolescents (B recommendation). ^64^ The Task Force recommended screening with a careful history of alcohol use or standardized screening questionnaires (AUDIT, CAGE), rather than biological markers such as serum GGT. It also recommended counseling all individuals who use alcohol about the dangers of operating a motor vehicle. And it recommended that pregnant women and women considering pregnancy should be told of the potential harm to the fetus from alcohol consumption, and be advised to reduce or quit drinking.

## Developments Since Last USPSTF Review

Screening Tools for Risky/Harmful Alcohol Use. Since the 1995 Task Force report, several screening tools have been further developed and evaluated for use in primary care populations. To update the Task Force's prior screening recommendations, we identified several good-quality recent reviews of screening for risky alcohol use in primary care—three systematic reviews ^44,^ ^65,^ ^66^ and two non-systematic reviews. ^55,^ ^67^ We also examined selected screening-related articles addressing measures commonly used (AUDIT, CAGE, TWEAK, and T-ACE) and deemed useful, reliable, and valid in primary care settings (see Appendix: Screening Instruments, for each instrument's specific questions, and Tables 3, 4, and 5, for summaries of the clinical applicability of screening instruments and sensitivity/specificity for specific clinical subgroups):

Table 3 Screening Tool Detail

Population | AUDIT | CAGE | TWEAK & T-ACE
Risky/Harmful Drinkers
Adults | Yes | No | No
65 years or older | perhaps (with lower cutoff) | No | No
Pregnant women | No | No | Yes
Adolescents | unknown/unclear | No | No
Alcohol Abuse or Dependence
Adults | Yes | Yes | Yes
65 years or older | perhaps (with lower cutoff) | perhaps (with lower cutoff) | unknown/unclear
Pregnant women | No | No | Yes
Adolescents | Yes | perhaps (with lower cutoff) | Perhaps TWEAK

Table 4 Screening Instrument Performance for Detecting Risky/Harmful Drinking in Primary Care Samples

Population | AUDIT | TWEAK
| sensitivity, specificity | sensitivity, specificity
Adults (cutpoint = 8) | .51–.97, .78–.96 ^44^ | N/A
(consider cutpoint of 5–6 for women) ^66^
Predominately older men | .57–.59, .91–.96 | N/A
(cutpoint = 8) ^68^
Pregnant women | N/A | .59–.87, .72–.94 ^65^ *
Adolescents | N/A | N/A

* cutpoints ranged from 1–3

Table 5 Screening Instrument Performance for Detecting Alcohol Abuse or Dependence in Health Care Settings

Population | AUDIT | CAGE | TWEAK
| sensitivity, specificity | sensitivity, specificity | sensitivity, specificity
All adults | .38–.96, .80–.96 ^65^ – ^67,^ ^44^ | .21–.94, .77–.97 ^65^ – ^67,^ ^44^ | .70–.87, .76–.87 ^67^
Men only | .56–.98, .73–.84 ^67^ | .47–.84, .80–.93 ^65^ | .48–.96, .68–.80 ^65,^ ^67^
Women only | .51–.85, .93–.97 ^65,^ ^67^ | .38–.83, .92–.96 ^65^ | .44–.80, .90–.95 ^65,^ ^67^
| (cutoff ≥ 8) | (cutoff ≥ 2) | (cutoff ≥ 3)
All older adults | not available | .48–.70, .82–.99 ^85,^ ^44^ | not available
≥ 65 yrs males only | .33, .91 ^84^ | not available
> 60 yrs males only | .55–.58, .95–.96 ^44^ | .53, 81 ^44^
Younger People
Teens (13–19 yrs) | .55, .96 ^88^ | .23, .96 ^88^ | .73, .90 ^88^
University students | .74, .92 ^90^ | .14, .97 ^90^ | not available
| (cutoff ≥ 8) | (cutoff ≥ 2) | (cutoff ≥ 2)

1 AUDIT: The AUDIT (Alcohol Use Disorders Identification Test) is a 10-item screening instrument developed by the World Health Organization to detect problem alcohol use and risk drinking among primary care patients. It includes 3 dimensions of alcohol-related risk/problems: (1) hazardous alcohol use—frequency of drinking, typical quantity, frequency of heavy drinking, (2) dependence symptoms—impaired control over drinking, increased salience of drinking, morning drinking, and (3) harmful alcohol use—guilt after drinking, blackouts, alcohol-related injuries, others concerned about drinking.
2 CAGE: The CAGE is a 4-item screening instrument designed to detect lifetime history of alcoholism that can be modified to detect recent/current alcoholism. The CAGE acronym reflects the following: “C” for feeling the need to “Cut” down on drinking, “A” for people annoying you by criticizing your drinking, “G” for feeling bad or guilty about your drinking, and “E” for having an “eye-opener” (a drink upon arising in the morning). The T-ACE is a modified version of the CAGE, designed to detect drinking and alcohol use disorders among pregnant women.
3 TWEAK: The TWEAK is a 5-item scale developed to screen for alcohol problems and risk drinking during pregnancy. “T” stands for tolerance, “W” stands for close friends/relatives worrying or complaining about your drinking, “E” for eye-openers, “A” for amnesia (blackouts), and “K” for feeling the need to cut down on drinking.

The most recent good-quality comprehensive systematic review of screening for alcohol problems in primary care supports the effectiveness of these screening instruments. ^44^ The authors reviewed 38 studies, (11 related to at-risk, harmful, or hazardous drinking) and reported that structured screening instruments have better sensitivity and specificity for detecting risky alcohol use and problems than unstructured quantity-frequency measures, clinical impressions, or laboratory tests, and that the literature supports using the AUDIT to screen for at-risk, harmful, and hazardous drinking. Other reviews and comparisons support the conclusions of this review. ^55,^ ^65^ – ^68^ The AUDIT was designed to increase detection of risky and harmful alcohol use, is more accurate than other screening tools for identifying such problems (sensitivity ranges from 51%–97%; specificity ranges from 78% to 96% ^44^ ), and predicts alcohol-related illness and social problems, hospitalization, and mortality. ^69,^ ^70^ Additionally, guidelines for scores appropriate for simple advice (8–15) brief counseling and continued monitoring (16–19), and referral for diagnostic evaluation for alcohol dependence (20 and above) are now available for the AUDIT. ^71^ To achieve true comparability in U.S. populations, AUDIT scoring should be adjusted for the U.S. standard drink, which is approximately 40% higher (14 grams) than the standard drink used in AUDIT (10 grams). ^71,^ ^72^

For detecting lifetime and current alcohol abuse and dependence disorders, the CAGE is superior to other commonly used screening tools (sensitivity ranged from 43% to 94%; specificity ranged from 70% to 97%). ^44^ In identifying less severe (i.e., risky/harmful) drinking patterns, however, the CAGE performs poorly compared to the AUDIT. ^44^ An alternative for detecting alcohol use disorders is to use the CAGE augmented with three additional quantity/frequency questions. This approach, suggested by the National Institute on Alcohol Abuse and Alcoholism in their 1995 “Physicians Guide to Helping Patients with Alcohol Problems” ^40^ (available online at http://www.niaaa.nih.gov/publications/physicn.htm), has been validated, ^73^ with sensitivity of 83% and specificity of 84% for detecting alcohol abuse or dependence in the prior 12 months.

Performance characteristics of both the CAGE and the AUDIT may differ somewhat by ethnicity and gender, ^44,^ ^74^ although the AUDIT was developed to be culturally sensitive, and other reports find no evidence of gender or racial/ethnic bias when it is used in primary care. ^75,^ ^76^

Special populations may benefit from use of particular screening instruments. The TWEAK and T-ACE perform well as screeners for alcohol problems among pregnant women. ^77^ – ^79^ Preliminary information suggests that the AUDIT may be useful for older adults, ^80^ – ^82^ which is important because the most common screening tools for older individuals (CAGE and the Michigan Alcoholism Screening Test-Geriatric Version [MAST-G]) identify dependence and abuse but not risky drinking. ^80,^ ^83^ – ^85^ Additionally, other screening tools are currently under development for identifying risky drinking among older primary care patients. ^86^ For adolescents in primary care settings, a recent examination of the CAGE—AA for adolescents (which included drug use), and the SSI-AOD (Simple Screening Instrument for Alcohol and Other Drug Abuse) found that both had acceptable reliability and internal consistency; sensitivity and specificity were not assessed. ^87^ Among injured adolescents in an emergency room setting, the AUDIT (with a cut point of 4) was best at identifying adolescents who met DSM-IV criteria for alcohol use disorders compared to the TWEAK and CAGE. ^88^ Similarly, studies of college students indicate that the AUDIT has good sensitivity (80–83%) and specificity (78–82%) for detecting alcohol abuse and dependence (using a cutpoint of 6). ^89,^ ^90^

Some clinicians may feel more comfortable asking about alcohol use in the context of a general health-risk interview. The AUDIT remains valid when embedded within a broader health-screening format. ^91^ Two other interview-based screening tools (the Health Screening Survey [HSS] and Health Survey Questionnaires [HSQ]) also embed alcohol-related questions in a series of other health behavior-related items. The HSS and HSQ, an older questionnaire on which HHS was based, cover CAGE augmented with some quantity and frequency questions (see Appendix). Both the HSS and HSQ have adequate sensitivity and specificity. ^2,^ ^92,^ ^93^

Compared to standardized questionnaires, biological markers of drinking status remain poor indicators of at-risk drinking. ^44^ However, they can be valuable in some patients for corroborating results of screening and monitoring abstinence. ^94^ Of these, carbohydrate deficient transferrin (CDT) and GGT appear to be the best indicators of high- or intermediate-risk consumption of alcohol, and may be best when used in combination. ^95^

Primary Care Behavioral Counseling Interventions for Risky/Harmful Alcohol Use. Since the last review of this topic by the USPSTF, a number of randomized controlled trials examining the results of brief interventions in primary care in the United States have been published, as have several systematic reviews and meta-analyses addressing brief interventions in primary care and other health care settings. ^96^ – ^99^ All of these were judged to meet the USPSTF criteria for good systematic reviews, and each of them supported modest improvements in alcohol use measures among at least some category of intervention groups compared with controls. However, each of these reviews was incomplete for the purposes of our review because they excluded a number of relevant trials more recently published, ^96^ – ^98^ included both primary care and non-primary care settings, ^96,^ ^97,^ ^99^ used summary outcomes that are difficult to interpret clinically, ^98^ or included trials of questionable quality. ^96,^ ^98,^ ^99^

To assist the USPSTF in updating its recommendation, the Oregon Evidence-based Practice Center undertook a systematic review of the evidence concerning behavioral counseling interventions to reduce risky/harmful alcohol use. We independently reviewed all relevant studies in the “early” intervention category to which we gave “fair” to “good” quality ratings. These included those identified through prior systematic reviews as well as those identified via searches.