# References

1 US Preventive Services Task Force. Guide to clinical preventive services. 2nd ed. Baltimore: Williams &Wilkins; 1996.
2 Cates WJ. Estimates of the incidence and prevalence of sexually transmitted diseases in the United States. American Social Health Association panel. Sex Transm Dis. 1999;26:S2-S7. [pmid: 10227693].
3 Groseclose SL, Zaidi AA, DeLisle SJ, Levine WC, St L, ME. Estimated incidence and prevalence of genital Chlamydia trachomatis infections in the United States, 1996. Sex Transm Dis. 1999;26:339-344. [pmid: 10417022].
4 Rolfs RT, Galaid EI, Zaidi AA. Pelvic inflammatory disease: trends in hospitalizations and office visits, 1979 through 1988. Am J Obstet Gynecol. 1992;166:983-990. [pmid: 1550176].
5 Stamm WE, Hicks CB, Martin D.H. et al. Azithromycin for empirical treatment of the nongonococcal urethritis syndrome in men. JAMA. 1995;274:545-549. [pmid: 7629982].
6 Centers for Disease Control and Prevention. Recommendations for prevention and management of Chlamydia trachomatis infections, 1993. MMWR Morb Mortal Wkly Rep. 1993;42:1-39. [pmid: 8418395].
7 Laga M, Manoka A, Kivuvu M, et al. Non-ulcerative sexually transmitted diseases as risk factors for HIV-1 transmission in women: results from a cohort study. AIDS. 1993;7:95-102. [pmid: 8442924].
8 Fleming DT, Wasserheit JN. From epidemiological synergy to public health policy and practice: the contribution of other sexually transmitted diseases to sexual transmission of HIV infection. Sex Transm Infect. 1999;75:3-17. [pmid: 10448335]. [pmcid: 1758168].
9 Institute of Medicine Committee on Prevention and Control of Sexually Transmitted Diseases. In: Eng TR, Butler WT, eds. The hidden epidemic: Confronting sexually transmitted diseases. Washington, DC: National Academy Press;1997.
10 Stamm WE, Holmes KK. Chlamydia trachomatis infections of the adult. In: Holmes KK, Mardh PA, Sparling PF, et al, eds. Sexually transmitted diseases. 2nd ed. New York: McGraw-Hill. 1990:181-193. [pmid: 2264006].
11 Stamm WE Chlamydia trachomatis infections: progress and problems J Infec Dis 1999 179(Suppl 2):380 383
12 Quinn TC, Gaydos C, Shepherd M, et al. Epidemiologic and microbiologic correlates of Chlamydia trachomatis infection in sexual partnerships. JAMA. 1996;276:1737-1742. [pmid: 8940322].
13 Hillis SD, Owens LM, Marchbanks PA, Amsterdam LE, MacKenzie WR. Recurrent chlamydial infections increase the risks of hospitalization for ectopic pregnancy and pelvic inflammatory disease. Am J Obstet Gynecol. 1997;176:103-107. [pmid: 9024098].
14 American College of Obstetricians and Gynecologists. Guidelines for women's health care. Washington, DC: American College of Obstetricians and Gynecologists; 1996.
15 Parks KS, Dixon PB, Richey CM, Hook EW 3rd. Spontaneous clearance of Chlamydia trachomatis infection in untreated patients. Sex Transm Dis. 1997;24:229-235. [pmid: 9101635].
16 Davies HD, Wang EE. Periodic health examination, 1996 update: 2. Screening for chlamydial infections. Canadian Task Force on the Periodic Health Examination. Can Med Assoc J. 1996;154:1631-1644. [pmid: 8646651]. [pmcid: 1487928].
17 HEDIS 2000: The health plan employer data and information set. Volume I: Narrative--what's in it and why it matters. Washington, DC: National Committee for Quality Assurance; 2000.
18 Centers for Disease Control and Prevention. 1998 guidelines for treatment of sexually transmitted diseases. MMWR Morb Mortal Wkly Rep. 1998;47:49-60. [pmid: 9461045].
19 Guidelines for perinatal care. 4th ed. Elk Grove Villages, IL: Americn Academy of Pediatrics;Washington, DC: American College of Obstetricians and Gynecologists; 1997.
20 Russell LB, Gold MR, Siegel JE, Daniels N, Weinstein MC. The role of cost-effectiveness analysis in health and medicine. Panel on Cost-effectiveness in Health and Medicine. JAMA. 1996;276:1172-1177. [pmid: 8827972].
21 Siegel JE, Weinstein MC, Russell LB, Gold MR. Recommendations for reporting cost-effectiveness analyses. Panel on Cost-effectiveness in Health and Medicine. JAMA. 1996;276:1339-1341. [pmid: 8861994].
22 Weinstein MC, Siegel JE, Gold MR, Kamlet MS, Russell LB. Recommendations of the Panel on Cost-effectiveness in Health and Medicine. JAMA. 1996;276:1253-1258. [pmid: 8849754].
23 Udvarhelyi IS, Colditz GA, Rai A, Epstein AM. Cost-effectiveness and cost-benefit analyses in the medical literature: are the methods being used correctly?. Ann Intern Med. 1992;116:238-244. [pmid: 1530808].
24 Centers for Disease Control and Prevention. Chlamydia trachomatis genital infections--United States, 1995. MMWR Morb Mortal Wkly Rep. 1997;46:193-198. [pmid: 9072679].
25 Addiss DG, Vaughn ML, Ludka D, Pfister J, Davis JP. Decreased prevalence of Chlamydia trachomatis infection associated with a selective screening program in family-planning clinics in Wisconsin. Sex Transm Dis. 1993;20:28-35. [pmid: 8430355]. [pmcid: 325049].
26 Mosure DJ, Berman S, Fine D, Delisle S, Cates W, Boring JR. Genital chlamydia infections in sexually active female adolescents: do we really need to screen everyone?. J Adolesc Health. 1997;20:6-13. [pmid: 9007653].
27 Herrmann B, Egger M. Chlamydia trachomatis infections in Uppsala County, Sweden, 1998-1993: declining rates for how much longer?. Sex Transm Dis. 1995;22:253-260. [pmid: 7482109].
28 Cleavenger RL, Juckett RG, Hobbs GR. Trends in chlamydia and other sexually transmitted diseases in a university health service. Coll Health. 1996;44:263-265.
29 Crowley T, Horner PJ, Nelki J, Caul EO. Screening associated with reduced infection rates. BMJ. 1994;308:716-717. [pmid: 8185737].
30 van Duynhoven YT, van de Laar MJ, Fennema JS, van Doornum GJ, van den Hoek JA. Development and evaluation of screening strategies for Chlamydia trachmatis infections in an STD clinic. Genitourin Med. 1995;71:375-381. [pmid: 8566977]. [pmcid: 1196108].
31 Katz BP, Blythe MJ, van der Pol B, Jones RB. Declining prevalence of chlamydial infection among adolescent girls. Sex Transm Dis. 1996;23:226-229. [pmid: 8724513]. [pmcid: 325352].
32 Centers for Disease Control and Prevention. Chlamydia prevalence and screening practices--San Diego County, California, 1993. MMWR Morb Mortal Wkly Rep. 1994;43:366-375. [pmid: 8183228].
33 Mertz KJ, Levine WC, Mosure DJ, Berman SM, Dorian KJ. Trends in the prevalence of chlamydial infections. The impact of community-wide testing. Sex Transm Dis. 1997;24:169-175. [pmid: 9132985].
34 Gaydos CA, Howell MR, Pare B, et al. Chlamydia trachomatis infections in female military recruits. New Eng J Med. 1998;339:739-744. [pmid: 9731090].
35 Mosure DJ, Berman S, Kleinbaum D, Halloran ME. Predictors of Chlamydia trachomatis infection among female adolescents: a longitudinal analysis. Am J Epidemiol. 1996;144:997-1003. [pmid: 8916511].
36 Finelli L, Nakashima AK, Hillis S, Crane E, Spitalny KC. Selective screening versus presumptive treatment criteria for identification of women with chlamydial infection in public clinics: New Jersey. Am J Obster Gynecol. 1996;174:1527-1533. [pmid: 9065124].
37 Bontis J, Vavilis D, Panidis D, Theodoridis T, Konstantinidis T, Sidiropoulou A. Detection of Chlamydia trachomatis in asymptomatic women: relationship to history, contraception, and cervicitis. Adv Contracept. 1994;10:309-315. [pmid: 7740997].
38 Park BJ, Stergachis A, Scholes D, Heidrich FE, Holmes KK, Stamm WE. Contraceptive methods and the risk of Chlamydia trachomatis infection in young women. Am J Epidemiol. 1995;142:771-778. [pmid: 7572949].
39 Oakeshott P, Kerry S, Hay S, Hay P. Opportunistic screening for chlamydial infection at time of cervical smear testing in general practice: prevalence study. BMJ. 1998;316:351-352. [pmid: 9487170]. [pmcid: 2665566].
40 Han Y, Coles FB, Hipp S. Screening criteria for Chlamydia trachomatis in family planning clinics: accoutning for prevalence and clients' charcteristics. Fam Plann Perspect. 1997;29:163-166. [pmid: 9258647].
41 Gunn RA, Hillis SD, Shirey P, Waterman SH, Greenspan JR. Chlamydia trachomatis infection among Hispanic women in the California-Mexico border area, 1993: establishing screening criteria in a primary care setting. Sex Transm Dis. 1995;22:329-334. [pmid: 8578402].
42 Gershman KA, Barrow JC. A tale of two sexually transmitted diseases. Prevalences and predictors of chlamydia and gonorrhea in women attending Colorado family planning clinics. Sex Transm Dis. 1996;23:481-488. [pmid: 8946633].
43 Neu NM, Grumet S, Saiman L, McMahon DF, Westhoff C. Genital chlamydial disease in an urban, primarily Hispanic, family planning clinic. Sex Transm Dis. 1998;25:317-321. [pmid: 9662767].
44 Burstein GR, Gaydos CA, Diener-West M, Howell MR, Zenilman JM, Quinn TC. Incident Chlamydia trachomatis infections among inner-city adolescent females. JAMA. 1998;280:521-526. [pmid: 9707141].
45 Sessa R, Latino MA, Magliano EM, et al. Epidemiology of urogenital infections caused by Chlamydia trachomatis and outline and characteristic features of patients at risk. J Med Microbiol. 1994;41:168-172. [pmid: 8064835].
46 Marrazzo JM, Fine D, Celum CL, DeLisle S, Handsfield HH. Selective screening for chlamydial infection in women: a comparison of three sets of criteria. Fam Plann Perspect. 1997;29:158-162. [pmid: 9258646].
47 Cook RL, St. George K, Lassak M, Tran N, Anhalt JP, Rinaldo CR. Screening for Chlamydia trachomatis infection in college women with a polymerase chain reaction assay. Clin Infect Dis. 1999;28:1002-1007. [pmid: 10452625].
48 Chout R, Vaton S, Quist D, Bucher R, Leguyader-Desprees P, Sayada C. Improvement of cervical chlamydia detection in asymptomatic family planning attendees by using Amplicor Chlamydia trachomatis assay. Cell Mol Biol. 1995;41:731-736. [pmid: 7580853].
49 Lisby G, Scheibel J, Abrahamsson L, Christensen ES, Paloheimo S. Detection of Chlamydia trachomatis in individual and pooled endocervical and urethral scrapes by a commercially available polymerase chain rection. APMIS. 1994;102:797-800. [pmid: 7826611].
50 Skulnick M, Chua R, Simor AE, et al. Use of the polymerase chain reaction for the detection of Chlamydia trachomatis from endocervical and urine specimens in an asymptomatic low-prevalence population of women. Diagn Microbiol Infect Dis. 1994;20:195-201. [pmid: 7705032]. [pmcid: 1376511].
51 Davis JD, Riley PK, Peters CW, Rand KH. A comparison of ligase chain reaction to polymerase chain reaction in the detection of Chlamydia trachomatis endocervical infections. Infect Dis Obstet. 1998;6:57-60.
52 Gaydos CA, Howell MR, Quinn TC, Gaydos JC, Mckee KT. Use of ligase chain reaction with urine versus cervical culture for detection of Chlamydia trachomatis in an asymptomatic military population of pregnant and nonpregnant females attending Papanicolaou smear clinics. J Clin Microbiol. 1998;36:1300-1304. [pmid: 9574695]. [pmcid: 104818].
53 van Doornum GJ, Buimer M, Prins M, et al. Detection of Chlamydia trachomatis infection in urine samples from men and women by ligase chain reaction. J Clin Microbiol. 1995;33:2042-2047. [pmid: 7559945]. [pmcid: 228332].
54 Ossewaarde JM, van Doornum GJ, Buimer M, Choueiri B, Stary A. Differences in the sensitivity of the Amplicor Chlamydia trachomatis PCR assay. Genitourin Med. 1997;73:207-211. [pmid: 9306903]. [pmcid: 1195824].
55 Crotchfelt KA, Welsh LE, DeBonville D, Roenstraus M, Quinn TC. Detection of Neisseria gonorrhoeae and Chlamydia trachomatis in genitourinary specimens from men and women by a coamplification PCR assay. J Clin Microbiol. 1997;35:1536-540. [pmid: 9163477]. [pmcid: 229782].
56 Hallsworth PG, Hefford C, Waddell RG, Gordon DL. Comparison of antigen detection, polymerase chain reaction and culture for detection of Chlamydia trachomatis in genital infection. Pathology. 1995;27:168-171. [pmid: 7567147].
57 Quinn TC, Welsh L, Lentz A, et al. Diagnosis by AMPLICOR PCR of Chlamydia trachomatis infection in urine samples from men and women attending sexually transmitted disease clinics. J Clin Microbiol. 1996;34:1401-1406. [pmid: 8735088]. [pmcid: 229032].
58 Toye B, Peeling RW, Jessamine P, Claman P, Gennill I. Diagnosis of Chlamydia trachomatis infections in asymptomatic men and women by PCR assay. J Clin Microbiol. 1996;34. [pmid: 8735087]. [pmcid: 229031].
59 Mahony JB, Luinstra KE, Sellors JW, et al. Role of confirmatory PCRs in determining performance of chlamydia amplicor PCR with endocervical specimens from women with a low prevalence of infection. J Clin Microbiol. 1994;32:2490-493. [pmid: 7814487]. [pmcid: 264089].
60 Haase AM, Bagshaw S, George PM. Improved detection of Chlamydia trachomatis in endocervical samples by using a new polymerase chain reaction assay. NZ Med J. 1995;108:292-294.
61 Schachter J, Stamm WE, Quinn TC, Andrews WW, Burczak JD, Lee HH. Ligase chain reaction to detect Chlamydia trachomatis infection of the cervix. J Clin Microbiol. 1994;32:2540-2543. [pmid: 7814494]. [pmcid: 264098].
62 Catry MA, Borrego MJ, Cardoso J, Azevedo J, Santo I. Comparison of the Amplicor Chlamydia trachomatis test and cell culture for the detection of urogenital chlamydial infections. Genitourin Med. 1995;71:247-250. [pmid: 7590718]. [pmcid: 1195523].
63 Carroll KC, Aldeen WE, Morrison M, Anderson R, Lee D, Mottice S. Evaluation of the Abbott LCx ligase chain reaction assay for detection of Chlamydia trachomatis and Neisseria gonorrhoeaein urine and genital swab specimens from a sexually transmitted disease clinic population. J Clin Microbiol. 1998;36:1630-1633. [pmid: 9620391]. [pmcid: 104891].
64 Bygdeman SM, Johansson M, Jonasson J, et al. Magic Lite Chlamydia immunoassay in urogenital samples and urine versus chlamydial culture. Int J STD AIDS. 1994;5:207-211. [pmid: 8061093].
65 Lee HH, Chernesky MA, Schachter J, et al. Diagnosis of Chlamydia trachomatis genitourinary infection in women by ligase chain reaction assay of urine. Lancet. 1995;345:213-216. [pmid: 7823713].
66 Schachter J, Moncada J, Whidden R, et al. Noninvasive tests for diagnosis of Chlamydia trachomatis infection: application of ligase chain reaction to first-catch urine specimens of women. J Infect Dis. 1995;172:1411-1414. [pmid: 7594691].
67 Ridgway GL, Mumtaz G, Robinson AJ, et al. Comparison of the ligase chain reaction with cell culture for the diagnosis of Chlamydia trachomatis infection in women. J Clin Pathol. 1996;49:116-119. [pmid: 8655675]. [pmcid: 500342].
68 Pasternack R, Vuorinen P, Pitkajarvi T, Koskela M, Miettinen A. Comparison of manual amplicor PCR, Cobas Amplicor PCR, and LCx Assays for detection of Chlamydia trachomatis infection in women by using urine specimens. J Clin Microbiol. 1997;35:402-405. [pmid: 9003605]. [pmcid: 229589].
69 Pasternack R, Vuorinen P, Pitkajarvi T, Kuukankorpi A, Miettinen A. Detection of Chlamydia trachomatis infections in women by Amplicor PCR: comparison of diagnostic performance with urine and cervical specimens. J Clin Microbiol. 1996;34:995-998. [pmid: 8815129]. [pmcid: 228938].
70 Gaydos CA, Ngeow YF, Lee HH, et al. Urine as a diagnostic specimen for the detection of Chlamydia trachomatis in Malaysia by ligase chain reaction. Sex Transm Dis. 1996;23:402-406. [pmid: 8885072].
71 Buimer M, van Doornum GJ, Ching S, et al. Detection of Chlamydia trachomatis and Neisseria gonorrhoeae by ligase chain reaction-based assays with clinical specimens from various sites: implications for diagnostic testing and screening. J Clin Microbiol. 1996;34:2395-2400. [pmid: 8880487]. [pmcid: 229278].
72 Chernesky MA, Jang D, Lee H, et al. Diagnosis of Chlamydia trachomatis infections in men and women by testing first-void urine by ligase chain reaction. J Clin Microbiol. 1994;32:2682-2685. [pmid: 7852556]. [pmcid: 264142].
73 Stary A, Schuh E, Kerschbaumer M, Gotz B, Lee H. Performance of transcription-mediated amplication and ligase chain reaction assays for detection of chlamydial infection in urogenital samples obtained by invasive and noninvasive methods. J Clin Microbiol. 1998;36:2666-2670. [pmid: 9705411]. [pmcid: 105181].
74 Grun L, Tassano-Smith J, Carder C, et al. Comparison of two methods of screening for genital chlamydia infection in women attending in general practice: cross sectional survey. BMJ. 1997;315:226-230. [pmid: 9253271]. [pmcid: 2127176].
75 Bassiri M, Hu HY, Domeika MA, et al. Detection of Chlamydia trachomatis in urine specimens from women by ligase chain reaction. J Clin Microbiol. 1995;33. [pmid: 7790456]. [pmcid: 228063].
76 Olafsson JH, Davidsson S, Karlsson SM, Palsdottir R, Steingrimsson O. Diagnosis of Chlamydia trachomatis infection in high-risk females with PCR on first void urine. Acta Derm Vener. 1996;76:226-227.
77 Paukku M, Puolakkainen M, Apter D, Hirvonen S, Paavonen J. First-void urine testing for Chlamydia trachomatis by polymerase chain reaction in asymptomatic women. Sex Transm Dis. 1997;24:343-346. [pmid: 9243741]. [pmcid: 325478].
78 Mouton JW, Verkooyen R, van der Meijden WI, et al. Detection of Chlamydia trachomatis in male and female urine specimens by using the amplified Chlamydia trachomatis test. J Clin Microbiol. 1997;35:1369-1372. [pmid: 9163445]. [pmcid: 229750].
79 Crotchfelt KA, Pare B, Gaydos C, Quinne TC. Detection of Chlamydia trachomatis by the Gen-Probe AMPLIFIED Chlamydia trachomatis Assay (AMP CT) in urine specimens from men and women and endocervical specimens from women. J Clin Microbiol. 1998;36:391-394. [pmid: 9466747]. [pmcid: 104548].
80 Pasternack R, Vuorinen P, Miettinen A. Evaluation of the Gen-Probe Chlamydia trachomatis transcription-mediated amplification assay with urine specimens from women. J Clin Microbiol. 1997;35:676-678. [pmid: 9041411]. [pmcid: 229649].
81 Oh MK, Smith KR, O'Cain M, Kilmer D, Johnson J, Hook EW 3rd. Urine-based screening of adolescents in detention to guide treatment for gonococcal and chlamydial infections. Translating research into intervention. Arch Pediatr Adolesc Med. 1998;152:52-56. [pmid: 9452708].
82 Green TA, Black CM, Johnson RE. Evaluation of bias in diagnostic-test sensitivity and specificity estimates computed by discrepant analysis. J Clin Microbiol. 1998;36:375-381. [pmid: 9466744]. [pmcid: 104545].
83 Scholes D, Stergachis A, Heidrich FE, Andrilla H, Holmes KK, Stamm WE. Prevention of pelvic inflammatory disease by screening for cervical chlamydial infection. N Engl J Med. 1996;334:1362-1366. [pmid: 8614421].
84 Stergachis A, Scholes D, Heidrich FE, Sherer DM, Holmes KK, Stamm WE. Selective screening for Chlamydia trachomatis infection in a primary care population of women. Am J Epidemiol. 1993;138:143-153. [pmid: 8356957].
85 Kamwendo F, Forslin L, Bodin L, Danielsson D. Decreasing incidences of gonorrhea and chlamydia-associated acute pelvic inflammatory disease. A 25-year study from an urban area of central Sweden. Sex Trans Dis. 1996;23:384-391.
86 Egger M, Low N, Smith GD, Lindblom B, Herrmann B. Screening for chlamydial infections and the risk of ectopic pregnancy in a country in Sweden: ecological analysis. BMJ. 1998;316:1776-1780. [pmid: 9624063]. [pmcid: 28575].
87 Sutton MY, Zaidi A, Sternberg M. Trends in hospitalized and ambulatory pelvic inflammatory disease in the United States. 48th Annual Epidemic Intelligence Service (EIS) Conference. Atlanta, GA; April 19-23, 1999.
88 Orr P, Sherman E, Blanchard J, Fast M, Hammond G, Brunham R. Epidemiology of infection due to Chlamydia trachomatis in Manitoba, Canada. Clin Infect Dis. 1994;19:876-883. [pmid: 7893873].
89 Oh MK, Richey CM, Pate MS, Brown PR, Hook EW 3rd. High prevalence of Chlamydia trachomatis infections in adolescent females not having pelvic examinations. J Adolesc Health. 1997;21:80-86. [pmid: 9248931].
90 Kent CK, Litchfield W, Whittington W, et al. Factors associated with persistent and recurrent chlamydial infection in women. International Congress of Sexually Transmitted Disease. Seville, Spain; October 18-22, 1995.
91 Shaw E, Roberts D, Connor PD. Prevalence of and risk factors for chlamydia in a rural pregnant population. J Fam Pract. 1995;41:257-260. [pmid: 7650505].
92 Chokphaibulkit K, Patamasucon P, List M, Moore B, Rodriguez H. Genital Chlamydia trachomatis infection in pregnant adolescents in East Tennessee: a 7-year case-control study. J Pediatr Adolesc. 1997;10:95-100.
93 Campos-Outcalt D, Ryan K. Prevalence of sexually transmitted diseases in Mexican-American pregnant women by country of birth and length of time in the United States. Sex Transm Dis. 1995;22:78-82. [pmid: 7624816].
94 Andrews WW, Lee HH, Roden WJ, Mott CW. Detection of genitourinary tract Chlamydia trachomatis infection in pregnant women by ligase chain reaction assay. Obstet Gynecol. 1997;89:556-560. [pmid: 9083312].
95 Thejls H, Gnarpe J, Gnarpe H, et al. Expanded gold standard in the diagnosis of Chlamydia trachomatis in a low prevalence population: diagnostic efficacy of tissue culture, direct immunofluorescence, enzyme immunoassay, PCR and serology. Genitourin Med. 1994;70:300-303. [pmid: 8001937]. [pmcid: 1195269].
96 Witkin SS, Inglis SR, Polaneczky M. Detection of Chlamydia trachomatis and Trichomonas vaginalis by polymerase chain reaction in introital specimens from pregnant women. Am J Obster Gynecol. 1996;175:165-167. [pmid: 8694044].
97 Brocklehurst P, Rooney G. Interventions for treating genital Chlamydia trachomatis infection in pregnancy. Cochrane Database of Systematic Reviews. 1998.
98 Wehbeh HA, Ruggeirio RM, Shahem S, Lopez G, Ali Y. Single-dose azithromycin for chlamydia in pregnant women. J Reprod Med. 1998;43:509-514. [pmid: 9653697].
99 Ryan GJ, Abdella T, McNeeley G, Baselski V, Drummond D. Chlamydia trachomatis infection in pregnancy and effect of treatment on outcome. AmJ Obstet Gynecol. 1990;162:34-39. [pmid: 2301514].
100 Cohen L, Veille JC, Calkins B. Improved pregnancy outcomes following successful treatment of chlamydial infection. JAMA. 1990;263:3160-163. [pmid: 2348525].
101 St. Louis ME, Ku L, Aral SO, et al. Prevalence of Chlamydia trachomatis infection among young men in the United States: a representative national survey. 13th Meeting of the International Society for Sexually Transmitted Diseases Research. Denver, CO; July 11-14, 1999.
102 Marrazzo JM, White CL, Krekeler B, et al. Community-based urine screening for Chlamydia trachomatis with a ligase chain reaction assay. Ann Intern med. 1997;127:796-803. [pmid: 9382400].
103 Lafferty WE, Hughes JP, Handsfield HH. Sexually transmitted diseases in men who have sex with men. Acquisition of gonorrhea and nongonococcal urethritis by fellatio and implications for STD/HIV prevention. Sex Transm Dis. 1997;24:272-278. [pmid: 9153736].
104 Oh MK, Cloud GA, Wallacek LS, Reynolds J, Surdevant M, Feinstein RA. Sexual behavior and sexually transmitted diseases among male adolescents in detention. Sex Transm Dis. 1994;21:127-132. [pmid: 8073340].
105 Gunn RA, Podschun GD, Fitzgerald G, et al. Screening high risk adolescent males for Chlamydia trachomatis infection. Obtaining urine specimens in the field. Sex Transm Dis. 1998;25:49-52. [pmid: 9437785]. [pmcid: 325502].
106 Poulin C, Alary M, Ringuet J, Frappier JY, Roy E, Lefebvre J. Prevalence of chlamydial infection and frequency of risk behaviours for STDs and HIV infection among adolescents in public juvenile facilities in the province of Quebec. Can J Public Health. 1997;88:266-270. [pmid: 9336096].
107 Urban MA, Coury-Doniger P, Reichman RC. Results of a screening program for Chlamydia trachomatis infection in men attending a sexually transmitted diseases clinic. Sex Transm Dis. 1997;24:587-592. [pmid: 9383848].
108 Harry TC, Saravananmuttu KM, Rashid S, Shrestha TL. Audit evaluating the value of routine screening of Chlamydia trachomatis urethral infections in mend. Int J STD AIDS. 1994;5:374-375. [pmid: 7819362].
109 Provision for sexual health care of adolescents in genitourinary medicine clinics in the United Kingdom. Genitourin Med. 1997;73:453-456. [pmid: 9582459]. [pmcid: 1195923].
110 Barrow RY, Mertz K, Mosure D, et al. Risk-based criteria for screening asymptomatic men for Chlamydia trachomatis infection: findings from a sexually transmitted disease clinic with universal testing. 47th Annual Epidemic Intelligence Service (EIS) Conference. Atlanda, GA; April 20-24, 1998.
111 Steingrimsson O, Olafsson JH, Sigvaldadottir E, Paldsottir R. Clinical evaluation of an automated enzyme-linked fluorescent assay for the detection of chlamydial antigen in specimens from high risk patients. Diagn Microbiol Infect Dis. 1994;18:101-104. [pmid: 8062526].
112 Stary A, Choueiri B, Horting-Muller I, Halisch P, Teodorowicz L. Detection of Chlamydia trachomatis in urethral and urine samples from symptomatic and asymptomatic male patients by the polymerase chain reaction. Eur J Clin Microbiol Infect Dis. 1996;15:465-471. [pmid: 8839640].
113 Higgins SP, Klapper PE, Struthers JK, al e. Detection of male genital infection with Chlamydia trachomatis and Neisseria gonorrhoeae using an automated multiplex PCR system (Cobas Amplicor). Int J STD AIDS. 1998;9:21-24. [pmid: 9518010].
114 Domeika M, Bassiri M, Mardh PA. Diagnosis of genital Chlamydia trachomatis infections in asymptomatic males by testing urine by PCR. J Clin Microbiol. 1994;32:2350-2352. [pmid: 7814464]. [pmcid: 264064].
115 Noren L, von Krogh G, Bondesson L, Nohlgard C, Grillner L. Potential public health benefits from testing with Chlamydia trachomatis PCR technique on first void urine in men. Acta Derm Venerol. 1998;78:63-66. [pmid: 9498032].
116 Wissenfeld HC, Uhrin M, Dixon BW, Sweet RL. Diagnosis of male Chlamydia trachomatis urethritis by polymerase chain reaction. Sex Trans Dis. 1994;21:268-271.
117 Chernesky MA, Chong S, Jang D, Luinstra K, Sellors J, Mahoney JB. Ability of commercial ligase chain reaction and PCR assays to diagnose Chlamydia trachomatis infections in men by testing first-void urine. J Clin Microbiol. 1997;35:982-984. [pmid: 9157168]. [pmcid: 229716].
118 Gun-Munro J, Mahony J, Lyn P, Luinstra K, Smaill F, Richardson H. Detection of Chlamydia trachomatis in genitourinary tract specimens using an automated enzyme-linked fluorescent immunoassay. Sex Trans Dis. 1996;23:115-119.
119 Talbot H, Romanowski B. factors affecting urine EIA sensitivity in the detection of Chlamydia trachomatis in men. Genitourin Med. 1994;70:101-104. [pmid: 8206466]. [pmcid: 1195203].
120 Moncada J, Schachter J, Shafer MA, et al. Detection of Chlamydia trachomatis in first catch urine samples from symptomatic and asymptomatic males. Sex Transm Dis. 1994;21:8-12. [pmid: 8140494].
121 Chernesky MA, Jang D, Sellors J, et al. Detection of Chlamydia trachomatis antigens in male urethral swabs and urines with a microparticle enzyme immunoassay. Sex Transm Dis. 1995;22:55-59. [pmid: 7709326].
122 Sanders JW, Hook EW 3rd, Welsh LE, Shepherd ME, Quinn, TC. Evaluation of an enzyme immunoassay for detection of Chlamydia trachomatis in urine of asymptomatic men. J Clin Microbiol. 1994;32:24-27. [pmid: 8126190]. [pmcid: 262963].
123 Domeika MA, Bassiri M, Mardh PA. Enzyme immunoassay and direct immunofluorscence for detection of Chlamydia trachomatis antigen in male first-void urine. Acta Derm Venereol. 1994;74:323-326. [pmid: 7976101].
124 Stary A, Tomazix-Allen S, Choueiri B, Burczak J, Steyrer K, Lee H. Comparison of DNA amplification methods for the detection of Chlamydia trachomatis in first-void urine from asymptomatic military recruits. Sex Transm Dis. 1996;23:97-102. [pmid: 8919734].
125 Chernesky MA, Lee H, Schachter J, et al. Diagnosis of Chlamydia trachomatis urethral infection in symptomatic and asymptomatic men by testing first-void urine in a ligase chain reaction assay. J Infect Dis. 1994;170:1308-1311. [pmid: 7963734].
126 Thorpe EM, Stamm WE, Hook EW 3rd. Chlamydial cervicitis and urethritis: single-dose treatment compared with doxycycline for seven days in community based practices. Genitourin Med. 1996;72:93-97. [pmid: 8698374]. [pmcid: 1195615].
127 Steingrimsson O, Olafsson JH, Thorarinsson H, Ryan RW, Johnson RB, Tilton RC. Single-dose azithromycin treatment of gonorrhea and infections caused by C. trachomatis and U. urealyticum in men. Sex Transm Dis. 1994;21:43-46. [pmid: 8140488].
128 Erdogru T, Agacfidan A, Onel M, Baldur S, Ang O, Telalloglu S. The treatment of nongonococcal urethritis with single-dose oral azithromycin. J Int Med Res. 1995;23:386-393. [pmid: 8529783].
129 Carlin EM, Barton SE. Azithromycin as the first-line treatment of nongonococcal urethritis (NGU): a study of follow-up rates, contact attendance and patients' treatment preference. Int J STD AIDS. 1996;7:185-189. [pmid: 8799780].
130 Bianchi A, Bogard M, Cessot G, Bohbot JM, Malkin JE, Alonso JM. Kinetics of Chlamydia trachomatis clearance in patients with azithromycin, as assessed by first void urine testing by PCR and transcription-mediated amplification. Sex Transm Dis. 1998;25:366-367. [pmid: 9713917].
131 Tanaka M, Matsumoto T, Kumazawa J, et al. Tosufloxacin in the treatment of nongonococcal urethritis, including Chlamydia trachomatis. Clin Ther. 1994;16:819-823. [pmid: 7859241].
132 Phillips I, Dimian C, Barlow D, et al. A comparative study of two different regimens of sparfloxacin versus doxycycline in the treatment of nongonococcal urethritis in mena. J Antimicrob Chemother. 1996;37:123-134. [pmid: 8737132].
133 Augenbraun M, Bachmann L, Wallace T, Dubouchet L, McCormack W, Hook EW 3rd. Compliance with doxycycline therapy in sexually transmitted diseases clinics. Sex Transm Dis. 1998;25:1-4. [pmid: 9437776]. [pmcid: 325494].
134 Romanowski B, Talbot H, Stadnyk M, Kowalchuk P, Bowie WR. Minocycline compared with doxycycline in the treatment of nongonococcal urethritis and mucopurulent cervicitis. Ann Intern Med. 1993;119:16-22. [pmid: 8498758].
135 Katz B, Zwickl B, Caine V, Jones R. Compliance with antibiotic therapy for Chlamydia trachomatis and Neisseria gonorrhoeae. Sex Transm Dis. 1992;19:351-354. [pmid: 1492264].
136 Jordan W. Doxycycline vs. tetracycline in the treatment of men with gonorrhea: the compliance factor. Sex Transm Dis. 1981;8:105-9.
137 Blonna R, Legos P, Burlack P. The effects of an STD education intervention on follow-up appointment keeping and medication taking compliance. Sex Transm Dis. 1989;16:198-200. [pmid: 2595518].
138 Bachmann LH, Stephens J, Richey CM, Hook EW 3rd. Measured versus self-reported compliance with doxycycline therapy for chlamydia-associated syndromes. Sex Transm Dis. 1999;26:272-278. [pmid: 10333280].
139 Marrazzo JM, Celum CL, Hillis SD, Fine D, DeLisle S, Handsfield HH. Performance and cost-effectiveness of selective screening criteria for Chlamydia trachomatis infection in women. Implications for a national Chlamydia control strategy. Sex Transm Dis. 1997;24:131-141. [pmid: 9132979]. [pmcid: 325419].
140 Howell MR, Quinn TC, Gaydos CA. Screening for Chlamydia trachomatis in asymptomatic women attending family planning clinics: a cost-effectiveness analysis of three strategies. Ann Intern Med. 1998;128:277-284. [pmid: 9471930].
141 Humphreys JT, Henneberry JF, Rickard RS, Beebe JL. Cost-benefit analysis of selective screening criteria for Chlamydia trachomatis infection in women attending Colorado family planning clinics. Sex Transm Dis. 1992;19:47-53. [pmid: 1561588]. [pmcid: 325016].
142 Sellors JW, Pickard L, Garni A, et al. Effectiveness and efficiency of selective vs. universal screening for chlamydial infection in sexually active young women. Arch Intern Med. 1992;152:1837-1844. [pmid: 1520050].
143 Genc M, Mardh A. A cost-effectiveness analysis of screening and treatment for Chlamydia trachomatis in asymptomatic women. Ann Intern Med. 1996;124:1-127. [pmid: 7503471].
144 Howell MR, Quinn TC, Brathwaite W, Gaydos CA. Screening women for Chlamydia trachomatis in family planning clinics: the cost-effectiveness of DNA amplification assays. Sex Transm Dis. 1998;25:108-117. [pmid: 9518379].
145 Gift TL, Pate MS, Hook EW 3rd, Kassler WJ. The rapid test paradox: when fewer cases detected lead to more cases treated: a decision analysis of tests for Chlamydia trachomatis. Sex Transm Dis. 1999;26:232-240. [pmid: 10225593]. [pmcid: 325649].
146 Nettleman MD, Bell TA. Cost-effectiveness of prenatal testing for Chlamydia trachomatis. Am J Obstet Gynecol. 1991;164:1289-1294. [pmid: 1903593].