# Acknowledgments

This systematic evidence review was prepared for the Agency for Healthcare Research and Quality (AHRQ) (Contract No. 290-97-0018, Task Order No. 2) to be used by the U.S. Preventive Services Task Force. Task Force members Carolyn Westoff, MD, MSc, and Jeffrey F. Peipert, MD, MPH, served as liaisons, and Paul S. Frame, MD, and Tracy A. Lieu, MD, MPH, were reviewers. Task Force Chair, Alfred O. Berg, MD, MPH, and AHRQ senior health policy analyst, David Atkins, MD, MPH, also contributed. Delia Scholes, PhD, was a consultant to the project. Oregon Health Sciences University Evidence-based Practice Center staff who contributed to this project include Kathryn Pyle Krages, AMLS, MA, administrator and Patty Davies, MS, librarian.