# Discussion

## Conclusions

Evidence obtained for the systematic review is summarized in Table 3. It indicates the type of study design and the quality of evidence for each key question.

Table 3. Overall summary of evidence

Key Questions | Evidence Codes* | Quality of Evidence**
Screening Nonpregnant Women
Arrow 1
Does screening reduce pelvic inflammatory disease? | I, II-3 | Good: 1 convincing RCT, other studies support findings.
Arrow 2
1. Does screening for chlamydia reduce the prevalence of infection? | II-3 | Poor to Fair: uncontrolled studies based on time trends after initiation of screening, studies from many populations and settings agree.
2. Are risk factors useful for selective screening? | II-2 | Fair: few studies in low prevalence, community populations, studies agree on age.
3. What screening tests should be performed? | II-1 | Fair: many studies about test performance under study conditions, not well tested in large screening populations with low prevalence.
Arrow 3
a. What are the implications of recurrent infection? | II-2 | Fair: high-risk subjects, lack of internal control groups, descriptive data.
Screening Pregnant Women
Arrow 2
1. Are risk factors useful for selective screening? | III | Poor: very few studies based on small populations, descriptive.
2. What screening tests should be performed? | II-1 | Fair: few studies about test performance under study conditions, not tested prospectively in large screening populations.
Arrow 3
1. Is treatment effective? Microbiologic cure | I | Good: RCTs available, although studies of new single-dose drugs are limited.
Effect on health outcomes | II-1, II-3 | Fair: not randomized, control group was based on temporal changes in treatment standards in 1 key study, differences between cases and controls not different in another study.
Screening Men
Arrow 2
1. Are risk factors useful for selective screening? | III | Poor: subjects mainly from STD clinics, jail, etc., descriptive.
2. What screening tests should be performed? | II-1 | Fair: many studies about test performance under study conditions, not tested prospectively in large screening populations with low prevalence.
Arrow 3
1. Is treatment effective? Microbiologic cure | I | Good: RCTs available for drug effects and compliance.
Effect on health outcomes | III | Poor: not studied, importance in transmission to women is an unresolved question.

*Evidence Codes Based on Study Design CategoriesI randomized, controlled trials, II-1 controlled trials without randomization, II-2 cohort or case-control analytic studies, II-3 multiple time series, dramatic uncontrolled experiments, III opinions of respected authorities, descriptive epidemiology.

**Quality of EvidenceGood, fair, poor categories are based on systematic consideration of three criteria: burden of suffering, characteristics of the intervention, and the effectiveness of the intervention as demonstrated in published clinical research.(From the U.S. Preventive Services Task Force, Guide to Clinical Preventive Services, 1996)^ 1 ^

Chlamydial infections present an ideal screening opportunity. It is the most common sexually transmitted bacterial pathogen in the United States and is capable of causing serious infections, such as PID, as well as long-term complications. Adolescents and young adults have the highest prevalence rates and are the most vulnerable to infectious sequela. Chlamydia is readily transmitted between sexual partners and to newborns. Many individuals who are infected, including the majority of infected women, do not have symptoms to prompt them to seek medical treatment. Most infections, therefore, are undetected in the absence of screening.

Despite the seriousness of chlamydia, it can be easily diagnosed by numerous new tests with high sensitivity and specificity that outperform the traditional gold standard of culture. The new urine tests, in particular, perform well in studies and provide a quick, noninvasive method. Cost studies, although limited, allude to the cost effectiveness of screening by urine testing. In addition, antibiotic regimens, including single-dose azithromycin, are effective in eradicating chlamydial infections.

The most compelling argument for screening in women is based on evidence for improvement of health outcomes. A randomized controlled trial of screening and treatment indicated a significant reduction in rates of PID among screened women compared with nonscreened women. Other studies provided indirect evidence to support these results. A time-series and a case-control study indicated improved birth outcomes when pregnant women were screened and treated.

The most difficult aspect of screening, however, is determining exactly whom to screen and how frequently to do so. The most consistent evidence available supports age-based screening in women. These strategies seem effective even in settings with low to moderate prevalence rates (3%-6%). Universal screening has been shown to be valuable in settings with higher prevalence rates (greater than 6%). Use of other selected risk factors may be helpful, but they vary between studies and may not translate to clinical settings. Cost studies indicate that, in women, screening is more cost effective than not screening. No new information on screening pregnant women is available. The evidence for screening in men is limited, although the rationale for screening is reasonable, based on indirect evidence. Little information is available on how frequently to screen any of these groups.

Treating partners is essential to prevent reinfection. Recurrent infections are associated with worse health outcomes, such as PID and ectopic pregnancies in women. Contract tracing and partner management, currently largely in the domain of public health programs, not clinical practices, were not reviewed in this report. As the responsibility for these duties shifts to HMOs, clinicians may become more involved in these secondary preventive measures.

## Balance Sheet

To demonstrate chlamydial screening outcomes based on assumptions from recent studies, we created a balance sheet for 10,000 women aged 18 to 34 years old (Table 4). In the first situation, a questionnaire is mailed to 10,000 women in a low-risk population (prevalence, 3%). Of 5,701 women who respond to the questionnaire, 713 are identified as high-risk and invited to have a chlamydia test. Of these, 457 have the test, and 32 are diagnosed with chlamydial infection and are treated. With this strategy, 9 cases of PID are prevented. The number needed to screen with a questionnaire to prevent 1 case of PID is 1,130. Eighty-one women would need to be invited for screening and 57 tested to prevent 1 case of PID.

Table 4. Screening for chlamydia in 10,000 women 18-34 years of age

| Low Risk (with Questionnaire)* | Low Risk (without Questionnaire) | High Risk**
Base Case Assumptions
Prevalence of chlamydia in population | 0.03 | 0.03 | 0.094
Compliance with chlamydia testing | 0.64 | 0.64 | 0.64
Sensitivity of test | 100% | 100% | 100%
Results
Mailed questionnaire | 10,000
Responded to questionnaire | 5,701
Identified as high risk | 713
Prevalence in risk group | 0.07 | 0.03 | 0.094
Tested for chlamydia | 457 | 6,400 | 6,400
Cases of chlamydia diagnosed and treated | 32 | 192 | 602
Cases of pelvic inflammatory disease (PID) prevented | 9 | 53 | 167
Number needed to screen (using questionnaire) to prevent 1 case of PID | 1,130 | not applicable | not applicable
Number needed to invite for screening (using chlamydia test) to prevent 1 case of PID | 81 (57)*** | 188 (120) | 60 (39)

*Assumptions based on the results of a randomized controlled trial conducted at Group Health of Puget Sound^83^ described in the text.

**Assumptions based on theoretical populations, the proportion of all patients who meet the criteria for high risk varies with practice setting, patient population, and the criteria used to define high risk.

***Numbers in parentheses indicate number needed to screen based on actual number of women tested for chlamydia.

If, instead of using a questionnaire, all women in this population were offered screening, 53 cases of PID might be prevented, but the number needed to invite for screening would be 188 (120 tested). In a high-risk population with a prevalence of 9.4%, offering a chlamydia test to all women could prevent 167 cases of PID, and the number needed to invite for screening would be 60 (39 tested). For this strategy, the number needed to screen depends heavily on the prevalence of disease. Figure 9 shows that the relation between the number needed to screen and the prevalence of chlamydia based on the balance sheet assumptions. The number needed to screen rises sharply at prevalence rates less than 3%.

Figure 9. Number needed to invite for screening to prevent 1 case of PID

## Research Priorities

The following studies and tests are research priorities:

- Studies testing screening criteria for both men and women in community-based settings to determine the effectiveness of various screening strategies. These strategies would include comparisons of universal, age-based, and risk-factor-based criteria among populations with various prevalence rates. Very little has been done to date to study screening strategies for men, and several investigators believe this should be a high priority. Also, studies should be coordinated to define representative populations that can be studied over time rather than continuing to do isolated cross-sectional convenience samples. A prospective approach would allow correct assessment of the performance of screening criteria, and this is important with a disease such as chlamydia, whose epidemiology is dynamic.
- Further testing of the effectiveness of urine chlamydia tests in community-based settings for nonpregnant women, pregnant women, and men. A CDC-funded multicenter study comparing the performance of PCR and LCR with culture and GenProbe in more than 6,000 men and women is currently nearly complete and will provide direction for future research in this area.
- Research on the role of the asymptomatic male for treatment or prevention in women.
- Studies of the effectiveness of screening in preventing infections and long-term complications as well as in reducing rates of transmission and recurrence in both sexes.
- Studies demonstrating appropriate screening intervals.
- Studies of the adverse effects of screening.
- Studies that provide a clearer understanding of the immunopathologic events leading to upper genital tract scarring and thus allow specific interventions to be targeted correctly.
- Studies of the significance of asymptomatic, culture-negative infections. Such CDC-affiliated studies are currently underway.
- Research on the effectiveness of screening in community-based settings.
- Studies that could provide evidence that screening is associated with decreased prevalence rates.
- High-quality cost analyses of current clinical options such as screening criteria, treatment regimens, types of diagnostic tests, partner notification, and screening intervals.