# Results

## Screening in Nonpregnant Women

### Does screening for chlamydia reduce the prevalence of infection?

No adequately controlled study has prospectively addressed the question of the prevalence rate of chlamydia infection being reduced with screening (Figure 1: Arrow 2; Figure 2: Arrow 2, Question 1). Changes in population prevalence rates have not been well documented because few studies have employed a representative population sample. Other unmeasured factors, such as condom use and changes in sexual behavior, could also be responsible for changes in prevalence rates.

Data from the CDC describe associations between screening programs and prevalence rates of chlamydial infection. Chlamydia screening and prevalence-monitoring activities were initiated in public health clinics in 4 Northwestern states in 1988 as a CDC-supported demonstration project (Region X includes Alaska, Idaho, Oregon, and Washington). The annual rate of chlamydia test positivity declined 65%, from 9.3% in 1988 to 3.3% in 1993, among women screened in Region X family planning clinics.^ 24 ^ In 1993 and 1995, similar programs were begun in the remaining regions. Preliminary data indicate similar short-term trends in some of these programs. From 1994 to midyear 1996, rates among women 19 years old or younger declined from 7.8% to 5.4% in Region III (Delaware, District of Columbia, Maryland, Pennsylvania, Virginia, and West Virginia) and from 5.5% to 4.6% in Region VIII (Colorado, Montana, North Dakota, South Dakota, Utah, and Wyoming).^ 24 ^ A statewide selective screening program for women attending family planning clinics in Wisconsin reported a similar decline in prevalence rates.^ 25 ^

Eight studies about screening and prevalence published since 1994 were identified from the literature review and met inclusion criteria (Evidence Table 1).^26-32^ Although these studies are considered in the same table, some of them describe population prevalence rates whereas others indicate clinic percent positivity rates. One study focused on the 15- to19-year-old cohort from the Region X program that was provided with routine chlamydia testing when patients underwent pelvic examinations.^ 26 ^ Infection rates decreased from 13.2% in 1988 to 7.6% in 1992. Another program for 13 to 19 year olds attending adolescent health clinics in Indiana offered routine testing, behavioral counseling, and contact tracing.^ 31 ^ Infection rates decreased from 25.9% in 1985 to 9.7% in 1994 based on first-visit data only. Two other papers found that despite significant declines in overall infection rates, the screening programs studied had less effect on trends for teenage cohorts.^27,33^

An extensive program in Sweden, initiated by national legislation, offered new clinics, contact tracing, health education, universal screening for women, and free evaluation and treatment. Prevalence rates decreased from 10.7% in 1985 to 3.2% in 1993 among women and from 18.3% to 7.1% among men.^ 27 ^

Several additional uncontrolled studies, conducted in specific clinic settings where patients presented for health care, reported similar results. Extrapolation of the results of these studies to a broader population may be limited. Declines in infection rates were reported in students routinely tested during pelvic examinations at a university health service clinic in West Virginia throughout a 5-year period,^ 28 ^ in women attending family planning clinics in San Diego,^ 32 ^ in women screened at 50 provider sites in the state of Ohio,^ 33 ^ in men and women presenting to an STD clinic in Amsterdam,^ 30 ^ and in men and women presenting to 2 genitourinary clinics in the United Kingdom.^ 29 ^

### Are risk factors useful for selective screening?

Additional research in recent years has further defined risk factors for chlamydial infection and tested them in predictive models to determine if selective screening has advantages over universal screening in certain populations (Figure 1: Arrow 2; Figure 2: Arrow 2, Question 2). This approach might save time and money because efforts are focused on individuals who would most likely benefit from testing and treatment. Further examination of studies relating to cost issues of selective and universal screening in women is detailed in this report (see Chapter 3, “Cost Studies”).

Sixteen studies published since 1994 describe risk factors for chlamydial infection among women tested in military, community, primary care, family planning, and STD clinics (Evidence Table 2).^26,30,34-47^ In 1 of the largest studies, 13,204 new female U.S. Army recruits from 50 states were universally screened and a prevalence rate of 9.2% was found.^ 34 ^ All women were asymptomatic and were screened by urine LCR. Independent associations for infection included age younger than 25 years, black or other nonwhite race, more than 1 partner or a new partner in the previous 90 days, not using a condom, and history of a previous STD. When the investigators tested the value of selective screening criteria in this population, using the risk factors of age younger than 25 years, more than 1 partner or a new partner in the previous 90 days, failure to use condoms in the previous 90 days, or history of a previous STD, they found that virtually all of the population would be eligible for screening. If they confined their criteria to all women 25 years old or younger, 87.9% of the population would need to be tested, and 95.3% of the positive subjects would be identified. Four other studies found that age alone or in combination with 1 or 2 other variables (race, marital status, symptoms, or physical findings) could detect 85% to 95% of infections.^36,39-41^

Figure 2. Key questions in analytic framework shown in figure 1

##### Screening Non-Pregnant Women

Arrow 1

1. Does screening reduce pelvic inflammatory disease?

Arrow 2

1. Does screening for chlamydia reduce the prevalence of infection?
2. Are risk factors useful for selective screening?
3. What screening tests should be performed?

Arrow 3

1. What are the implications of recurrent infection?

##### Screening Pregnant Women

Arrow 2

1. Are risk factors useful for selective screening?
2. What screening tests should be performed?

Arrow 3

1. Is treatment effective?

##### Screening Men

Arrow 2

1. Are risk factors useful for selective screening?
2. What screening tests should be performed?

Arrow 3

1. Is treatment effective?

Another study of 28,000 15- to19-year-old women seeking care in Region X family planning clinics also identified several factors independently associated with infection.^26,35^ No single risk factor or combination of risk factors was particularly sensitive for selective screening. The group with the fewest risk factors in this study (21%) accounted for 17% of all infections and had a 6% chlamydia prevalence rate (overall prevalence was 12.3%). Two other studies conducted in settings with greater than 20% prevalence rates also concluded that no risk factors could adequately select which women to screen in their populations.^30,44^

One study tested the usefulness of three sets of selective screening criteria in more than 37,000 female patients who had known risk-factor data and test results and who were originally universally screened.^ 46 ^ Prevalence rates ranged from 3.3% to 6.6% in the three different populations from family planning and STD clinics. Criteria included

1. CDC recommendations: age younger than 20 years; age 20 to 24 if she had a new partner or more than 1 partner in 90 days or had inconsistent use of barrier contraceptives; age 25 years or older if she had a new partner or multiple partners and they were also inconsistent users of barrier contraceptives.
2. Region X criteria: age younger than 21 years or a new partner within previous 30 days, more than 2 partners within previous 60 days, or a partner who has STD symptoms.
3. Age-based criteria alone: assessing cutoffs at both age younger than 21 years and younger than 25 years.

The CDC criteria performed best overall; 88% to 89% of infections were detected with screening 58% to 74% of women. Criteria based on age alone (younger than 25 years of age) performed best among women from family planning clinics. Prevalence rates were lower in the family planning clinics than in the STD clinics, with 84% to 92% of cases detected by means of screening 59% to 71% of the women.

Table 1 summarizes significant risk factors from the studies detailed in Evidence Table 2. Nearly all studies, representing a wide range of settings and prevalence rates (2.3%-21.5%), reported age as an important predictor (usually expressed as younger than 25 years old). Current Task Force,^ 1 ^ CDC,^ 6 ^ and other recommendations already use age as the primary determinant for screening. Five studies also reported black and other nonwhite race as being significantly associated. Other factors such as marital status, urban location, and low income were reported by 1 or 2 studies. Frequently cited behavioral risk factors include multiple partners, new partners, partner who had symptoms of an STD, and inconsistent use of or no barrier contraception. Personal history of PID, STD, douching, and oral contraceptive use were also noted as risk factors in some studies. Most studies found that physical findings, symptoms, and coexistent gonorrheal infection were also predictive of chlamydial infection. These factors, however, would necessitate chlamydial testing for reasons other than screening and would not be helpful in forming a selective screening strategy.

Table 1. Summary of risk factor studies for chlamydia in women

Reference | Cook et al 1999^ 47 ^ | Oakeshott et al 1998^ 39 ^ | Gunn et al 1995^ 41 ^ | Park et al 1995^ 38 ^ | Bontis et al 1994^ 37 ^ | Gershman and Barrow 1996^ 42 ^ | Han et al 1997^ 40 ^ | Neu et al 1998^ 43 ^ | Sessa et al 1994^ 45 ^ | Marrazzo et al 1997^ 46 ^ | Gaydos et al 1998^ 34 ^ | Finelli et al 1996^ 36 ^ | Mosure et al 1996^ 35 ^ | van Duyn-hoven et al 1995^ 30 ^ | Burstein et al 1998^ 44 ^
Prevalence | 2.3% | 2.9% | 3.5% | 3.8% | 4.0% | 4.5% | 2.2-7.2% | 5.4% | 5.0-6.8% | 8.6% | 9.2% | 7.5-14.6% | 12.3% | 21.5% | 24.1%
Demographic
Age <20 | x | | x | x | | x | x | x | | x | | x
Age <=24 | | x | x | x | x | x | x | x | x | | x | x | | x
Unmarried | | | x | x | | | | | | | | x
Black | x | x | | x | | x | | | | 0 | x | x | x
Other nonwhite | | | | | | x | | | | 0 | x | | x
Urban | | | | | | 0 | | | | | | x
Low income | | | | x | | | | 0
Nulliparous | | | | x
Behavioral
Inconsistent/no
barrier use | | 0 | | 0 | | | | | | 0 | x | 0 | x | | x
Oral contraception | | | | 0 | x | | | x* | x | | | | x
New partner^†^ | | | | | | | | | | | x | | x
>=1 partner^‡^ | | x | | x | x | x | | 0 | x | x | x | | x
Partner who has STD/symptoms | x | | | | | x | | | | | | | x | | x
History of STD | x | | | | | | | | | | x | | x
History of PID | | | | | x
Douching | | | | x
Findings
Friability | | x | x | | x | x | | x | | | | | x | x
Discharge | | x | x | | x | x | | x | | x | | 0 | x | x
Ectopy | | | | | x | | | x
Diagnoses
Gonorrhea | | | | | | | | x | | | | x
Pregnant | | | | | | | | x | | | | 0 | x

*Associated with a lower risk for chlamydia in this study.

^†^Defined in most studies as a new partner within the previous 1 to 3 months.

^‡^Definition varies with studies from 4 or more lifetime partners to more than 1 partner per year.

These studies do not completely agree on what risk-assessment criteria would be appropriate for screening most women. Some existing criteria, such as those recommended by the CDC, performed well when applied to screening populations described above.^ 46 ^ Part of the problem with efforts to develop selective screening criteria in which variables other than age are used is that different parts of the country are addressing problems at different epidemiologic phases. For example, mature programs are more likely detecting incidence rates and newer programs, prevalence rates. Also, some investigators indicated that obtaining behavioral information from patients was more difficult and less reliable than obtaining demographic data; thus the usefulness of behavioral information is compromised. The study about universal screening among female military recruits detected chlamydial infections among some of the women who claimed they had never had vaginal sex.^ 34 ^

### What screening tests should be performed?

We focused on the new DNA amplification tests in which both cervical swabs and urine specimens were used. Thirty-three studies^48-80^ compared 2 or more of these tests in the same study population and were included in the systematic review (Figure 1: Arrow 2; Figure 2: Arrow 2, Question 3). (See Evidence Table 3.) These include 22 studies reporting culture results,^48,50,52,53,55-58,61,65-69,71-73,75,76,78-80^ 11 antigen-detection tests,^49,50,54,56,60,64,70,72,74,75,77^ 15 LCR,^51-53,61,63,65-68,70-75^ 17 PCR,^48-51,54-60,62,68,69,76,77,80^ and 4 transcription-mediated amplification of RNA tests.^73,78-80^ Studies in which antigen-detection tests with cervical swabs were compared with culture were not reviewed here because the performance of antigen-detection tests has been previously acknowledged, and antigen-detection tests are currently widely used in clinical practice.

Although culture is 100% specific for chlamydial infection (i.e., no false positives), there is growing recognition that culture is not 100% sensitive and, therefore, is not an acceptable gold standard for assessing newer diagnostic technologies. Investigators have advocated the use of an expanded gold standard for the calculation of sensitivity and specificity of assays. In this case, a positive result is defined by a positive culture or a negative culture with a positive either PCR or LCR test that has been confirmed positive by a DFA assay or a PCR or a LCR test directed against the major outer membrane protein (MOMP). In these studies, however, the additional confirmation tests are usually performed only on specimens that had discrepant results from 2 or more other tests. These tests themselves often constitute part of the expanded gold standard, particularly when culture is not used in the study.

Culture specimens had 100% specificity (because most studies defined culture as the gold standard) and widely varying sensitivity, ranging from 42% to 100% (Figure 3). Results of the antigen-detection tests obtained with cervical swab (EIA, DFA) indicate improved sensitivity, with most results between 70% and 80%, but with some decline in specificity (96%-100%) (Figure 4). Only 4 studies^64,70,72,75^ evaluated antigen-detection urine tests and found these to have low sensitivity (15%-64%), but high specificity (99%-100%).

Figure 3. Summary of diagnostic test (culture) studies in women

Figure 4. Summary of diagnostic test (antigen detection) studies in women

Results of the studies of the new DNA amplification tests, PCR and LCR, indicate higher sensitivity and specificity than the antigen-detection tests (Figure 5). PCR swab specimens had sensitivities of 82% to 100% and specificities of 98% to 100%; PCR urine tests had sensitivities of 82% to 100% and specificities of 98% to 100%. LCR swab specimens had sensitivities of 81% to 98% and specificities of 96% to 100%; LCR urine tests had sensitivities of 70% to 96% and specificities of 99% to 100%. Results for the transcription-mediated amplification of RNA tests were not graphed because only 4 studies were identified from our search. These performed well, with sensitivities and specificities for urine and swab specimens comparable with the DNA amplification tests.

Figure 5. Summary of diagnostic test (DNA amplification) studies in women

These results indicate that cervical swab specimens and first-void urine specimens had similar performance when DNA amplification tests were used. Urine tests allow noninvasive testing for women without the need for a pelvic examination, thereby expanding opportunities for screening.^ 81 ^ No studies addressed the adverse effects of using these newer technologies, although experts in the field note that some laboratories have had technical problems with the tests.

Methodologic inconsistencies were noted upon review of the papers. Discrepant analysis in chlamydia testing is often performed when culture-negative, new-test-positive specimens undergo 1 or more additional tests to determine whether the positive test result can be confirmed. Although use of discrepant analysis is very common in test performance studies, it is biased and can overestimate sensitivity and specificity results, depending on the reference test.^ 82 ^

### Does screening for chlamydia in women reduce pelvic inflammatory disease?

The best evidence to date about the effectiveness of screening for chlamydial infection in preventing pelvic inflammatory disease (PID) (Figure 1, Arrow 1) is a randomized controlled trial conducted in a large health maintenance organization (HMO) population in Seattle.^ 83 ^ Inclusion criteria for subjects were based on an earlier study of chlamydia prevalence and risk factors conducted in the primary care clinics of the same HMO in Seattle.^ 84 ^ In this study of 1,692 largely asymptomatic young women, the prevalence of chlamydial infection was 3.5%. An age of younger than 25 years, black race, nulligravidity, 2 or more sexual partners in the past year, douching within the past year, presence of cervical ectopy, and being unmarried were independently associated with an increased risk of chlamydial infection.

For the screening trial, married women were excluded because of their low prevalence of infection in the earlier study. Pregnant women were also excluded. Cervical ectopy was excluded as a risk factor for screening because an examination is necessary to determine its presence. All women enrollees 18 to 34 years of age were mailed a questionnaire to determine their risk status based on the other factors. Each woman was assigned a risk score based on age (24 years or younger, 1 point), race (black, 2 points), nulligravidity (1 point), douching (1 point), and having 2 or more sex partners in the preceding 12 months (1 point). The factors in this score were those found in the previous study^ 84 ^ to be independently associated with chlamydial infection by use of stepwise multivariate logistic regression. The model was rerun for this trial without married women and cervical ectopy variables. Of the remaining significant associations, race had the highest OR and was given 2 points in the score. Those who had a score of 3 or more were eligible for the screening trial.

Eligible women were randomly assigned to a screening group or a usual care group. Participants in the screening group were provided with endocervical EIA and cultures and those who had positive results were treated. After 12 months of follow-up, participants from both groups completed questionnaires about health outcomes and behavior. HMO databases were examined for diagnostic and treatment information, and medical records were reviewed for outcomes.

Screening and treatment of chlamydial infections in asymptomatic women in this study was associated with a significantly reduced incidence of PID after 1 year of follow-up. A total of 645 women in the screening group (64%) were tested for chlamydia, and 7% had positive tests and were treated. The 1,598 women in the usual care group were not tested. After 12 months, there were 9 confirmed cases of PID among women in the screening group (8/10,000 women-months) and 33 among women in usual care (18/10,000 women-months;relative risk [RR] 0.44; 95% confidence interval [CI], 0.20-0.90). Adjustment for various combinations of baseline characteristics did not alter the reduction in risk of PID associated with screening.

Long-term outcomes such as rates of recurrences, ectopic pregnancies, infertility, or chronic pelvic pain were not addressed in this study. Also, women younger than 18 years of age, a group with generally higher prevalence rates than older women, were not included. The study groups represent the results of a 2-step process of identifying risk factors in a given population and of then applying them in the same population as the inclusion criteria. These risk factors have not been tested as screening criteria. Also, note that the invitation to participate was obtained after randomization, and only 64% of those invited to screening participated. Since outcomes were not assessed for those who declined participation, there is a potential bias if they were at higher risk than the enrollees. With application of the criteria of this study, screening of 100 women was performed and resulted in identification of 7 infections and prevention of slightly more than 1 case of PID.

Two ecological analyses of chlamydia screening and reduction of PID and ectopic pregnancy agree with these results. Both studies were conducted in Sweden, where an extensive national program for chlamydia detection and treatment was initiated during the mid-1980s. A steady decrease in PID began in 1987 and reached its lowest level in 1994, with the biggest decrease occurring among 15 to19 year olds.^ 85 ^ Similar decreasing trends in ectopic pregnancies, considered a later complication of PID, were reported in a separate study of trends from 1985 to1995.^ 86 ^ The timing of the decline varied with age, with an immediate reduction noted in young women.

A research abstract from the CDC found that hospitalized cases of PID in the United States declined 57% from 1981 through 1996.^ 87 ^ At the same time, outpatient visits for PID showed no significant change, indicating a true overall decline.

### What are the implications of recurrent infection?

Recurrent chlamydial infections in women have been associated with increased risks for PID and long-term complications (Figure 1, Arrow 3). In a recently published retrospective cohort study, the risks of hospitalization was evaluated for ectopic pregnancy or PID for 11,000 Wisconsin women who had documented single and recurrent chlamydial infections.^ 13 ^ Rates of hospitalization for ectopic pregnancy increased with the number of infections (13/10,000 for 1 infection, 49/10,000 for 2, 140/10,000 for 3 or more). Similarly, rates of hospitalization for PID also increased with the number of infections (11/10,000 for 1, 54/10,000 for 2, 110/10,000 for 3 or more). Adjusted multivariate analyses indicated that women who had 2 and 3 or more chlamydial infections had elevated risks of ectopic pregnancy compared with those who had 1 infection (2 infections: OR 2.1, 95% CI, 1.3, 3.4; 3 or more infections: OR 4.5, 95% CI, 1.8, 5.3), and elevated risks for PID (2 infections: OR 4.0, 95% CI, 1.6, 9.9; 3 or more infections: OR 6.4, 95% CI, 2.2, 18.4). Recurrent or persistent chlamydial infections were more likely to occur among women who were young, black, residents of Milwaukee County (large urban population), received care in STD clinics, or had documented gonorrhea infection.

Although the clinical importance of recurrent chlamydial infections in women is acknowledged, information about the effectiveness of screening for recurrence is limited. This type of information would be helpful in determining screening intervals for groups at risk of recurrences. We found 3 studies that evaluated recurrence rates in high-risk teenage populations. These studies did not differentiate between recurrences due to reinfection and treatment failures. In a prospective study of 3,202 high-risk, sexually active women 12 to 19 years of age, it was found that the median time to the first positive chlamydia test result was 7.2 months and only 6.3 months to a repeat positive test among those who had repeat visits.^ 44 ^ In a study of chlamydia infection among residents of Manitoba, it was found that 13.4% of those initially infected had a subsequent recurrent infection.^ 88 ^ In this study, recurrence was more common in women than in men, in those 15 to 24 years age, in registered Native American Indians, and in those who had concomitant gonorrhea. In another study of sexually active urban adolescents in Birmingham, AL, an initial chlamydial infection rate of 23.2% was detected. Of those initially infected, 20.8% presented with a positive test on follow-up.^ 89 ^

Persistent and recurrent chlamydial infections in women presenting to STD, family planning, and adolescent clinics was evaluated in a research abstract from the CDC.^ 90 ^ Of the participants, 6% had chlamydial infections detected at 1-month follow-up visits and 7.5%, at 4 months. Factors related to persistence and recurrence were young age (14-21 years) and incomplete therapy.

### Summary

Recent studies of screening for chlamydial infection in nonpregnant women indicate

- The initiation of screening programs in multiple settings and communities is associated with declines in chlamydial infection prevalence rates in the populations these settings and communities serve. However, other unmeasured factors may be contributing to these favorable trends. There are limitations on what inferences can be drawn from this ecological data.
- Age continues to be the best predictor of chlamydial infection in women, with most studies evaluating cutoffs at age younger than 25 years.
- Other risk factors may be useful predictors, but these are likely to be population specific.
- A selective screening strategy incorporating population-specific prevalence rates and risk factors may be effective. However, the use of screening criteria developed in one population may not translate to others, with the exception of age. Pilot studies may need to be done to determine prevalence rates and risk factors in certain geographic areas or clinic settings before adapting selective screening strategies to them. For populations with high prevalence rates, universal screening may be necessary. Also, universal screening may be necessary to detect an acceptable proportion of cases.
- When DNA amplification tests such as PCR and LCR are used, first-void urine specimens provide results comparable with specimens from a cervical swab. The use of urine testing in women would allow noninvasive screening that could be performed outside the context of a pelvic examination.
- No studies that addressed the adverse effects of screening in nonpregnant women were identified.
- There is evidence from a randomized controlled trial that screening susceptible women for chlamydia decreases cases of PID.
- Recurrent infections are clinically important for women because they increase the risk for PID and for ectopic pregnancy.
- Recent studies of recurrence rates are limited, but rates are substantial when measured in high-prevalence settings.
- Little evidence about optimal screening intervals for women exists.

## Screening in Pregnant Women

### Are risk factors useful for selective screening?

Depending on the population studied, previous studies have reported prevalence rates for chlamydial infections in pregnant women ranging from 2% to 31%. Very few previous studies described risk factors for infection (Figure 1: Arrow 2; Figure 2: Arrow 2, Question 1). Three recent studies^91-93^ conducted in the United States reported both prevalence rates and risk factors in pregnant women.

A study conducted in a rural area in Tennessee indicated a prevalence rate of 9.0% in a sample of 347 patients.^ 91 ^ Factors predictive of a positive test included single marital status, black race, history of STDs, presence of gonorrhea during the current pregnancy, being younger than 20 years of age, and late onset of prenatal care. Another study of 596 pregnant teenagers, also located in Tennessee, reported a prevalence rate of 11.24%.^ 92 ^ Independent associations were significant for black race and greater gestational age at first prenatal visit. In a third study conducted with 347 women from a Mexican-American population in Arizona found, a prevalence rate of 10.1% was found.^ 93 ^ The only variable associated with infection in this study was presence of a vaginal discharge.

### What screening tests should be performed?

Few studies compared screening test performance in pregnant women (Figure 1: Arrow 2; Figure 2: Arrow 2, Question 2). Two studies compared urine LCR with endocervical culture in pregnant women and found LCR to be more sensitive and easier to use than culture.^52,94^ Another study compared culture with DFA, EIA, and PCR (all obtained with endocervical swabs) and concluded that the nonculture techniques provided improved sensitivity compared with culture even in a population with a prevalence rate as low as 4.3%.^ 95 ^ Another study reported 100% specificity and 97.2% sensitivity by use of PCR on swab-obtained introital specimens compared with PCR endocervical specimens.^ 96 ^

### Is treatment effective?

#### Microbiologic cure

Treatment for pregnant women differs because doxycycline, a preferred treatment regimen for chlamydia, is contraindicated (Figure 1, Arrow 3). The CDC therefore recommends a test of cure during treatment of pregnant women because treatment with amoxicillin or erythromycin is less efficacious than treatment with doxycycline.^ 18 ^

A Cochrane review of 11 trials of interventions for treating genital C trachomatis infection in pregnancy concluded that amoxicillin was as effective as erythromycin in achieving microbiological cure (OR 0.54, 95% CI, 0.28-1.02).^ 97 ^ Amoxicillin was associated with fewer side effects than erythromycin (OR 0.16, 95% CI, 0.09-0.30). The review also stated that clindamycin and azithromycin seemed effective, though the numbers of women included in those trials were small. Of the 5 trials located in our search, 4 were included in this Cochrane review. The fifth study was published after the review, and its results were that single-dose azithromycin was more effective and had fewer side effects than a standard course of erythromycin.^ 98 ^ Despite the lack of studies of azithromycin, many physicians are currently prescribing it for pregnant women. We found no studies that addressed the adverse effects of treatment in pregnant women.

#### Effect on health outcomes

The second Task Force recommendations for screening pregnant women were based on 2 studies demonstrating improved pregnancy outcomes after treatment of chlamydial infection.^ 1 ^ We identified no recent studies on this topic in our literature search, but reviewed these 2 studies for relevance.

A time-series design study included 11,544 women presenting to their first prenatal visit between 1982 and 1985 in Memphis.^ 99 ^ All were cultured for chlamydia, and 21.1% were positive. The 1,110 positive patients seen during the first 16 months of the study were not treated for infection because this was not yet the standard of care. The 1,323 women seen during the remaining months were treated with antibiotics and checked with a test of cure. Untreated patients had a significantly higher incidence of premature rupture of membranes and low birth weight and a lower infant survival rate compared with treated patients and patients who had negative cultures. The investigators encouraged chlamydia screening and treatment of pregnant women at risk for infection.

The second study was a case-control investigation comparing chlamydia-positive pregnant women who remained culture positive throughout their pregnancy despite treatment, chlamydia-positive women who were successfully treated, and chlamydia-free control patients who were never treated.^ 100 ^ The frequencies of premature rupture of membranes, premature contractions, and small-for-gestational-age infants were significantly lower among the successfully treated patients compared with the chlamydia-positive patients who were unresponsive to treatment; however, the frequency of occurrence for these conditions was not significantly different when compared with the control patients.

### Summary

- New information about chlamydia screening in pregnant women is limited.
- Risk factors for infection in pregnant women have not been extensively studied. Risk factors from studies in nonpregnant populations are often used to describe high-risk groups of pregnant women.
- Nonculture testing techniques appear to perform well in pregnant populations, although studies are limited.
- Amoxicillin and erythromycin are equally effective treatments for chlamydial infection in pregnant women, although few studies have evaluated single-dose azithromycin in this population. These regimens require a test of cure because they are less efficacious than doxycycline.
- Treating infected women reduces adverse pregnancy outcomes.
- No studies addressed the adverse effects of screening in pregnant women.
- No evidence was found that describes when and how often to screen during pregnancy, but screening late in pregnancy is advocated by the CDC to reduce chlamydia transmission at birth.^ 6 ^

## Screening in Men

### Are risk factors useful for selective screening?

The prevalence of chlamydial infection among men varies widely (less than 2% to more than 45%), depending on the population tested and types of diagnostic tests used (Figure 1: Arrow 2; Figure 2: Arrow 2, Question 1). Unfortunately, most published studies about prevalence and risk factors in men were conducted in STD clinics or detention facilities and do not generalize well to community-based settings. Lack of accessibility to men at risk remains a major obstacle for screening studies and programs.

An abstract of findings from the 1995 National Survey of Adolescent Males (NSAM) indicated prevalence rates for chlamydia tested by means of urine PCR in a national household survey performed in the United States.^ 101 ^ The prevalence among sexually active men 18 to 19 years old was 4.2% (95% CI, 1.9-6.5), and among single, noncohabiting sexually active men 22 to 26 years old, it was 8.3% (95% CI, 4.2-12.3). Rates varied by racial groups, with black men 18 to 19 years of age having a rate of 15.4% (95% CI, 8.6-22.1) and white men 18 to 19 years of age having a rate of 1.2% (95% CI, 0.0-2.9). These findings have not yet been published in a journal.

Evidence Table 4 summarizes 14 published studies about prevalence and risk factors in men.^27,30,45,55,79-81,89,101-106^ Of these studies 7^30,45,57,103,107-109^ were performed exclusively in STD or genitourinary clinics, and 7^27,81,88,102,104-106^ were conducted in other settings. A multiple-site study in Seattle included 5,150 males with a median age of 16, with 98.6% of subjects asymptomatic.^ 102 ^ Their prevalence rate was 5.4% by LCR (urine). Prevalence rates obtained by means of culture specimens in STD clinics varied from 2.5% to 15.8% in Seattle^ 103 ^ and in the Netherlands, respectively.^ 30 ^ Three studies^81,104,106^ were performed in youth detention clinics in which rates varied from 3.0% by EIA (swab and urine) in Montreal to 8.8% by LCR (urine) in Alabama.

Risk factors for chlamydial infections in men have been much less studied than for women. The most cited risk factor is age, with men younger than 25 years of age considered at higher risk than those older than 25 years old. Peak incidence occurs among older adolescents and younger adult men. Six^27,30,45,102,107,109^ of the prevalence studies described in Evidence Table 4 reported independent associations with demographic and behavioral variables. A multiple-site study of adolescents in Seattle reported increased ORs for infection within the cohort for nonwhite race or ethnicity, 2 or more sex partners in the previous 2 months, presence of symptoms, and increasing age.^ 102 ^ Using a condom was associated with a reduced OR for infection. Five other studies concurred that age groups younger than 25 years were at increased risk of infection.^27,30,45,107,109^ One of these studies reported elevated ORs with early onset of sexual activity (younger than 13 years old) and with known STD in a partner.^ 30 ^

A research abstract from the CDC stated that among 4,797 asymptomatic men presenting to STD clinics in Ohio, those younger than 30 years of age, with more than 1 sexual partner in the past month or with a sexual partner who was a syphilis patient, had higher risks for chlamydia infection.^ 110 ^ Use of these risk factors as screening criteria in this low-prevalence cohort (1.3%) would have resulted in screening 73% of men and in detecting 93% of infections. No studies have been published, however, that prospectively test risk-factor screening criteria in men.

### What screening tests should be performed?

One of the biggest obstacles to screening for chlamydial infection in men has been the unacceptability of the diagnostic test itself (Figure 1: Arrow 2; Figure 2: Arrow 2, Question 2). Women are most often tested in the context of a pelvic examination, during which obtaining an additional swab has not usually been perceived by them as a barrier to testing. For men, however, the procedure of obtaining a urethral swab is often seen as uncomfortable, inconvenient, and unacceptable, particularly among men who have no symptoms. Until recently, this was the only method available. The development of urine testing has provided an opportunity to improve screening strategies for men.

To determine the accuracy of screening tests for men, we reviewed 30 studies on test performance (Evidence Table 5).^53-58,62-64,70-73,78,79,111-125^ These include 15 studies^53,55-58,71-73,78,79,111,117,121,122,125^ reporting culture results, 21 antigen-detection tests,^54,56,58,63,64,70,72,111-124^ 9 LCR,^53,63,70-73,117,124,125^ 13 PCR,^54-58,62,112-117,124^ and 3 transcription-mediated amplification of RNA.^73,78,79^ These studies compare 2 or more of these tests in the same study population.

Results for culture specimens indicate 100% specificity (because most studies defined culture as the gold standard) and widely varying sensitivity, ranging from 37% to 97% (Figure 6). Results of the antigen-detection tests (EIA, DFA) indicate improved sensitivity compared with culture, with most results averaging 80%, but with some decline in specificity (96%-100%) (Figure 7). Results of the studies of the new DNA amplification tests, PCR and LCR, indicate higher sensitivity and specificity than the antigen-detection tests (Figure 8). Results for the transcription-mediated amplification of RNA tests were not graphed because only 3 studies were identified from our search.

Figure 6. Summary of diagnostic test (culture) studies in men

Figure 7. Summary of diagnostic test (antigen detection) studies in men

Figure 8. Summary of diagnostic test (DNA amplification) studies in men

Results of swab specimens compared with first-void urine specimens in which the same technology was used were similar for DNA amplification tests. These results indicate that the performance of urine tests in the study populations was the same if not better than the comparable test obtained by use of swab specimen. The new DNA amplification tests performed best overall compared with culture or antigen-detection tests.

In most of the studies cited in Evidence Table 5, discrepant analysis (29 of 30 studies) was used. As described in the section on screening tests for women, discrepant analysis, although commonly used in test performance studies, is biased and can overestimate sensitivity and specificity results.

Another methodologic problem with these diagnostic test studies is the variability of study populations. Most populations studied were not community based. Most studies were conducted in STD clinics and many were located outside of the United States. The study population usually included both symptomatic and asymptomatic men and few studies reported results separately. Studies also varied in how they described symptoms. Also, very little demographic information was provided about the study population. The lack of test performance studies in a community-based, lower-prevalence population limits their generalizability, although in 1 epidemiologic study of more than 5,000 asymptomatic young males in Seattle, urine LCR was used in a community population.^ 102 ^

Although studies indicate that urine techniques can improve sensitivity compared with culture, the importance of detecting and treating culture-negative infections is not yet known. Asymptomatic, culture-negative infections may represent those who have lower organism counts. The clinical importance and rate of transmission of these low-level infections have not yet been studied.

### Is treatment effective?

#### Microbiologic cure

The results of clinical trials previously published and considered by the second Task Force indicated that azithromycin and doxycycline are equally efficacious and that both are more efficacious than erythromycin. See Figure 1, Arrow 3.

We identified only a few treatment studies of men who had chlamydial infection. Three randomized trials compared single-dose azithromycin with 7 days of twice-daily doxycycline. All studies concluded that a single dose of azithromycin was as effective as a 7-day course of doxycycline, with eradication rates ranging from 83% to 99%.^5,126,127^ In 2 nonrandomized trials, similar eradication rates were reported.^128,129^ Complete clearance of 18/19 patients after 7 days and of all patients after 14 days was indicated in another study in which clearance of chlamydia after 1 dose of azithromycin treatment by sequential PCR testing was examined.^ 130 ^

Two other studies compared doxycycline with sparfloxacin and tosufloxacin and found them to be comparable.^131,132^ These medications, however, are not commonly used in the United States.

Although these studies reported comparable effectiveness of drug regimens, other studies indicated important differences in compliance rates. One trial comparing single-dose to multiple-dose regimens reported that members of the multiple-dose group made additional clinic visits because of mislaid medications or compliance problems. In this study, more than 70% of patients questioned expressed a preference for single-dose therapy.^ 129 ^ Another study determined compliance with a 7-day course of doxycycline for men treated for chlamydial infections with a pill bottle fitted with a microprocessor in the cap that recorded both the date and the time of bottle openings and closings.^ 133 ^ Of the 223 enrolled participants, 80% returned their bottles at the end of treatments. Only 25% were considered fully compliant (twice-daily dosing on 6 of 7 days), 51% partially compliant (at least once-daily dosing on 5 of 7 days), and 24% noncompliant. These rates fall below those of previous studies that reported 60% to 70% compliance rates with multiple-dose treatment for STDs.^134-137^

Another study, however, recently found that, despite poor compliance with multiple doses of doxycycline, the treatment failure rate was only 6%.^ 138 ^ The single-dose advantage may not be as important as initially believed.

A randomized trial of azithromycin and doxycycline reported adverse reactions that were mild to moderate, occurring in 23% of the azithromycin group and in 29% of the doxycycline group.^ 5 ^ These were predominantly gastrointestinal symptoms, including nausea, diarrhea, esophagitis, and dyspepsia.

#### Effect on health outcomes

No studies were found that described the effectiveness of screening or early treatment for men in reducing transmission to women or in preventing acute infections or complications in men. Many investigators advocate screening men as the next essential step to reduce infections, complications, and recurrences in women, as well as to improve the health of men themselves. However, these health outcomes have not yet been studied. It is also not resolved whether efforts should be placed on screening men to improve outcomes for women as opposed to expanding services to women directly.

### Summary

- Studies of prevalence rates and risk factors for chlamydial infection in men are limited in number and generalizability. Predictive factors have not been tested in large screening populations of men as they have been for women. Age younger than 25 years is probably the strongest known risk factor cited so far.
- Urine tests offer a feasible method of chlamydia screening for men.
- DNA amplification techniques offer improved sensitivity and are more readily available compared with culture. Despite their lower specificity than culture, most studies report specificity greater than 95%.
- The effectiveness of urine tests in screening a large, community-based population of men requires additional study.
- The 2 recommended antibiotic treatment regimens have equal effectiveness under ideal circumstances. Despite better compliance with single-dose treatment with azithromycin than with multiple-dose treatment with doxycycline, cure rates are similar.
- No studies were identified that addressed the adverse effects of screening in men.
- No studies were identified that provided evidence of treatment effectiveness in reducing transmission to women, in reducing reinfection rates in men, or in preventing adverse health outcomes for men.

## Cost Studies

We retrieved 8 cost-effectiveness or cost-benefit analyses that either compared universal versus selective screening or evaluated the efficiency of various screening tests in nonpregnant and in pregnant women. Among the studies reviewed, few were of high quality. No studies conformed to the 4 selected criteria from the Panel on Cost Effectiveness in Health and Medicine (Table 2). Three studies met the 6 methodologic criteria of Udvarhelyi et al.^ 23 ^ No studies measured effectiveness by use of quality-adjusted life years or any other measure that could be used for comparisons with other interventions not related to STDs. Two studies used the societal perspective, and 2 others modeled indirect costs in sensitivity analyses (Evidence Table 6). In all studies, researchers used decision analytic modeling, employing data from the published literature and from site-specific screening studies; in all studies, researchers used data from STD and family planning clinics and such data, therefore, may not be generalizable to other settings. All studies were modeled for 1-time screening; none accounted for recurrent infection.

Table 2. Compliance with recommendations of the Panelon Cost Effectiveness in Health and Medicine

Author/Year | Societal Perspective | Costs in Fixed-Year $$ | 3%-5% Discount Rate | Multiway Sensitivity Analyses
Marrazzo et al^ 139 ^/1997 | + | + | + | -
Howell et al^ 140 ^/1998 | - | + | + | +
Humphreys et al^ 141 ^/1992 | - | - | - | -
Sellors et al^ 142 ^/1992 | - | + | + | +
Genc and Mardh^ 143 ^/1996 | + | - | + | +
Howell et al^ 144 ^/1998 | - | + | + | +
Gift et al^ 145 ^/1999 | - | + | - | +
Nettleman and Bell^ 146 ^/1991 | - | - | - | -

+=Yes; -=No

### Cost-Effectiveness of Universal Versus Selective Screening

Four studies addressed the cost effectiveness of universal versus selective screening strategies. In the first study, a selective screening strategy based on age (younger than 21 years of age) and at least 1 other risk factor (more than 2 partners in 60 days, new partner in 30 days, partner who had more than 2 partners, partner who had discharge or dysuria) was compared with universal screening in Region X family planning and STD clinics.^ 139 ^ Chlamydia prevalence was similar in both clinic settings (6.6% versus 6.7%). Selective and universal screening both decreased costs compared with no screening in either clinic setting. In STD clinics, 94% of cases were detected with selective screening, and this was the most cost-effective strategy in the reference case analysis. However, in family planning clinics, only 74% of cases were detected with selective screening, and this was less cost effective than universal screening. Sensitivity analysis suggested that universal screening would also be the dominant strategy in STD clinics if the prevalence of chlamydia infection was greater than 6.9%. These results depended on the assumption that at least 15% of untreated chlamydia infections would progress to PID. Selective screening was generally more cost effective than universal screening if the rate of progression to PID was assumed to be less than 15%.

In the second study, consisting of predominantly black women, screening women younger than 30 years of age provided cost savings compared with no screening, universal screening, or screening based on CDC recommendations.^ 140 ^ However, universal screening became dominant if the proportion of cases occurring in women 30 years of age and older increased from the reference case value of 7% to 12% or if the prevalence of chlamydia infection increased to more than 10.2%. The efficiency of universal screening depended on the availability of inexpensive specimen processing through a noncommercial laboratory.

The third study found that universal screening dominated selective screening (3 or more partners in 12 months or 21 years of age or younger with new partner in 2 months) in a population with 7.7% prevalence.^ 141 ^ The authors did not report the proportion of cases detected by the selection criteria or conduct any sensitivity analyses. Again, both screening strategies decreased costs compared with no screening.

In the fourth study, 2 selective screening strategies (based on selection criteria developed within their patient population) were compared with universal screening in Canadian family planning clinics.^ 142 ^ The authors found that selective screening, which captured 87% to 100% of chlamydia cases, saved costs over universal screening, as long as prevalence was less than 16%.

Four studies assessed the cost effectiveness of various screening tests in nonpregnant women. In the first study, which predated clinical use of DNA amplification tests, it was found that cervical EIA was more cost effective than culture or the combination of EIA and culture.^ 142 ^

In the second study, it was found that screening with cervical DNA amplification tests (PCR or LCR) was more cost-effective than EIA when chlamydia prevalence was greater than 4% to 6%.^ 143 ^ Culture was the least cost-effective test. In this study, the following values for sensitivity and specificity were used: culture 50% to 90%, 100%; EIA 70% to 80%, 99% to 100%; DNA amplification tests 87% to 98%, 99% to 100%.

In the third study, 7 different screening tests (culture, EIA, PACE 2 nonamplified probe assay, cervical and urine PCR, cervical and urine LCR) were compared.^ 144 ^ The sensitivity and specificity of culture in this study were assumed to be 85% and 100%, respectively. Assuming sensitivities and specificities for cervical LCR of 93% and 99% and for urine LCR of 90% and 99%, the investigators found that cervical LCR was the dominant strategy among women receiving routine pelvic examinations and that urine LCR was the dominant strategy for women in whom pelvic examination was not otherwise indicated. Performing pelvic examinations for the purpose of chlamydia screening with cervical LCR in the latter group would have added costs of $28,000 per case of PID prevented.

In the fourth study, a rapid cervical specimen test, optical immunoassay (OIA), was compared with cervical PCR and culture.^ 145 ^ Assuming sensitivities and specificities of 63% and 100% for OIA, 94% and 100% for PCR, and 80% and 100% for culture, the authors found that a strategy of initial OIA, with PCR for OIA-negative cases, was most cost effective. The value added by OIA was that it could be done before women left the clinic and would therefore diminish the number of cases that went untreated because of lack of follow-up. If at least 95% of women testing positive returned for treatment, PCR alone was the most cost effective. OIA alone was the most cost effective if the prevalence of infection was 5% or less. These results were sensitive to the cost and the accuracy of the tests.

One study compared the cost effectiveness of 3 different testing strategies (culture versus direct antigen test versus direct antigen test with confirmatory culture) in pregnant women.^ 146 ^ The respective sensitivity and specificity for culture were assumed to be 82% and 100%, and for direct antigen testing, 82% and 96%. All strategies increased costs compared with no screening when prevalence of chlamydia infection was less than 6.1%. Above this threshold, direct antigen testing alone was the dominant strategy. These results were sensitive to changes in assumptions regarding the costs of testing and to the inclusion of indirect costs. The study assumed universal screening and did not assess the effect of selective screening strategies.

### Summary

In recent economic studies of screening for chlamydia in women, the societal perspective was infrequently used, and these studies were generally not of high quality. Researchers did not address screening interval or recurrent infection. Study results may not be generalizable to settings other than family planning or STD clinics. Findings from these studies, however, with particular attention to studies of higher quality, suggest that

- Screening programs for detecting and treating chlamydia in nonpregnant women may provide cost savings in populations with moderate to high prevalence of chlamydia infection.
- Selective screening is more cost-effective than universal screening under most assumptions. Universal screening may be cost-effective in certain populations where the prevalence of chlamydia is high or the sensitivity of selective screening criteria is low.
- If current estimates of the accuracy of DNA amplification assays are reasonable, these tests may improve the cost effectiveness of chlamydia screening.
- The cost effectiveness of screening for pregnant women, using selective screening criteria and new tests, is uncertain.