# Methods

## Literature Search Strategy

We searched the topic of chlamydia in the MEDLINE, the HealthSTAR, and the Cochrane Library databases from January 1994 to November 1999; PubMed was searched for recent articles not yet indexed in MEDLINE. We searched cost studies in the same databases from January 1989 to November 1999. (See Appendix 2: Chlamydia Search Terms for the literature search terms.)

A single reader reviewed all English abstracts. Papers were selected for full review if they were about C. trachomatis genitourinary infections in men, nonpregnant women, or pregnant women and were relevant to key questions in the analytic framework or if they were related to cost. Reviews, policy statements, and other papers with contextual value were also obtained from the searches. Studies published as abstracts were not included in the search, although pertinent abstracts may be referred to in the text but not included in evidence tables. Review of reference lists of other relevant papers identified additional studies. Experts in the field also supplied references. Papers published before 1994 were cited if important to the interpretation of more recent papers.

## Data Extraction and Synthesis

We assigned evidence codes to all studies based on study design categories: I, randomized controlled trial; II-1, controlled trial without randomization; II-2, cohort or case-control analytic study; II-3, multiple time-series or drastic uncontrolled experiments; and III, opinions of respected authorities or descriptive epidemiology. Studies were also graded on the quality of evidence. Good, fair, and poor categories are based on systematic consideration of 3 criteria, including burden of suffering, characteristics of the intervention, and the effectiveness of the intervention as demonstrated in published clinical research. These codes are provided for studies relating to each key question in a summary table in the “Conclusions” section of this report. Cost studies were evaluated by different criteria as described below.

### Nonpregnant Women

We systematically reviewed 3 types of studies about screening in nonpregnant women that relate to 3 key questions: (1) studies about the effectiveness of screening programs in reducing prevalence rates of infection, (2) studies about risk factors for chlamydial infection in women, and (3) studies about chlamydia screening tests in women. Inclusion and exclusion criteria for each type of study are detailed below.

Studies about screening programs were included if they provided descriptions of the study population, including number of women screened, age range, setting, and other available sociodemographic factors. Screening program features such as time course of the study, type of testing (universal versus selective), features of the program (testing, counseling, contact tracing), and type of chlamydia test (endocervical versus urine; culture, antigen detection, or DNA amplification) were also abstracted from each study. Finally, outcome measures were recorded as prevalence rates at the beginning of the study period compared with those at a point several years later.

Studies of risk factors for chlamydial infection were included if they reported the number of women screened, age, setting, reason for visit, and other sociodemographic factors. Screening criteria used (universal versus selective), type of chlamydia test, other forms of data collection (e.g., questionnaire), and prevalence rate of the tested population were detailed. Results included odds ratios (ORs) for chlamydial infection from univariate or multivariate regression analysis and significance levels for comparisons between infected and noninfected women. When reported, we also noted risk factors that were not significantly related to chlamydial infection. Summaries of screening strategies were abstracted from studies in which they were described (e.g., if all women 25 years old or younger in our study were screened, 87% of the population would need to be tested and 95% of the positive subjects would be identified). We listed all significant associations in a table to create a nonstatistical summary of the 15 abstracted studies.

Studies of chlamydia screening tests were particularly complex. We focused on the new DNA amplification tests obtained with both swab and urine specimens. Studies of test performance were included only if they met quality criteria, including: (1) the test was appropriately performed in a standardized manner, (2) the index test, gold standard or expanded gold standard, and discrepant test were appropriately used, (3) the study population was adequately described, and (4) data were sufficient to determine the sensitivity and specificity of tests. We abstracted the type of test and specimen used, definition of the gold standard test and specimen used, definition of the discrepant test and specimen used, and definition of criteria for the expanded gold standard. Data describing the study population included number of women tested; proportion without symptoms;setting, age, and other sociodemographic factors; and prevalence of infection. Outcome measures included sensitivity, specificity, positive predictive value, and negative predictive value of tests evaluated. These outcome measures were then summarized in graphs plotting sensitivity by 1 minus specificity for a nonstatistical comparison of the different types of tests.

### Pregnant Women

Our search found too few studies on pregnant women to create evidence tables. Pertinent studies are described in Chapter 3, Results.

### Men

We systematically reviewed 2 types of studies about screening in men: (1) studies about prevalence rates and risk factors for chlamydial infection for men, and (2) studies about chlamydia screening tests in men.

Studies about chlamydia risk factors and prevalence in men were included in evidence tables if they described the study design; number of men tested; proportion of men who were asymptomatic; age range; other sociodemographic factors, such as race; setting; and type of test used. Outcome measures included prevalence and significant associations of risk factors with infection.

Studies of chlamydia screening tests for men were abstracted in a similar way as that described above for women. We focused particularly on the performance of urine tests because this type of testing would have the biggest effect on screening strategies for men.

### Cost Studies

We systematically reviewed cost studies related to screening in nonpregnant and pregnant women. We restricted our review to cost-effectiveness and cost-benefit studies. Other economic analyses (e.g., cost of illness, cost minimization) were not included. We reviewed 2 types of studies: (1) studies comparing selective with universal screening, and (2) studies comparing chlamydia screening tests.

Data abstracted from cost studies included descriptions of the study setting and population, interventions compared, analytic perspective, primary measure of effectiveness, cost data sources, and discount rate. Results of reference case analyses were summarized as cost-effectiveness or cost-benefit ratios, unless an intervention provided cost savings, in which case the intervention was described as dominant. Results of sensitivity analyses were included as available. Study quality was assessed by examining compliance with selected recommendations from the Panel on Cost Effectiveness in Health and Medicine^20-22^ and with a set of published methodologic quality criteria developed by Udvarhelyi et al.^ 23 ^