# Introduction

In this systematic evidence review, we examine data on the effectiveness of screening for chlamydial infection by a physician or other health care professional. Specifically, we examine the evidence of the effectiveness of screening strategies in nonpregnant women, pregnant women, and men; the accuracy of tests used for screening; as well as evidence that early treatment of chlamydial infection improves health outcomes. This review updates the literature since the last recommendation of the U.S. Preventive Services Task Force (USPSTF) published in 1996.^ 1 ^

## Burden of Suffering

Chlamydia trachomatis is the most common sexually transmitted bacterial pathogen in the United States, affecting an estimated 3 million individuals yearly.^2,3^ Chlamydial genital tract infections are a major cause of urethritis, cervicitis, and pelvic inflammatory disease (PID) in women and are an important cause of ectopic pregnancy, infertility, and chronic pelvic pain. Chlamydial infections are responsible for 25% to 50% of the 2.5 million cases of PID that are reported annually in the United States.^ 4 ^ Infections are also related to adverse pregnancy outcomes such as miscarriage, premature rupture of membranes, and preterm labor. Perinatal transmission to infants can cause neonatal conjunctivitis and pneumonia. Chlamydial infection in men is the cause of 10% to 20% of the 4 to 6 million visits each year for nongonococcal urethritis^5,6^ and of 50% of the more than 150,000 cases of acute epididymitis.^ 6 ^ Some men may experience chronic complications of infertility, chronic prostatitis, reactive arthritis, and urethral strictures. Chlamydia is a cofactor in transmission of human immunodeficiency virus (HIV) infection.^7,8^ In the United States in 1994, the estimated cost of untreated chlamydial infections and their complications was $2 billion.^ 9 ^

Chlamydial infections are particularly insidious because approximately 25% of men and 70% to 90% of women are asymptomatic.^ 10 ^ Since most men tested for chlamydia are those who present for care because they are symptomatic or because they are a sexual contact of an infected woman, it is likely that an even higher proportion of infected men are asymptomatic. Chlamydial infections have been associated with infertility and ectopic pregnancy in women even who lack clinical symptoms. The sequelae of chlamydial infections may be due to immunopathologically mediated events related to predisposition of specific patients as well as to the type of chlamydial strain.^ 11 ^ The high risk in young women probably reflects both behavioral and physiologic factors such as increased exposure of cervical columnar epithelium.^ 11 ^ Chlamydia is readily transmitted between sexual partners,^ 12 ^ and infected men and women who do not have symptoms serve as important reservoirs for new infections. Recurrent infections are associated with worse clinical outcomes for women. Rates of hospitalization for ectopic pregnancy and PID increase with the number of recurrent chlamydial infections.^ 13 ^

The prevalence of chlamydial infection varies from negligible to almost 40%, depending on the population. Chlamydia has the highest prevalence among groups who are least likely to regularly see a physician. Age is the strongest predictor of infection, with adolescent females and young adult males recording the highest rates. Most screening programs target young females in sexually transmitted disease (STD) or family planning clinics to take advantage of the opportunity to obtain diagnostic tests in the context of other services. Young males have been much more difficult to study and screen, but their roles in transmitting initial and recurrent infections in women are important. Others considered at higher risk include those having multiple sex partners, a new sex partner, or an infected sex partner; those who inconsistently use barrier contraceptives;those who have previous or coexistent STDs; and women who have abnormalities on examination such as vaginal discharge, cervicitis, cervical friability, and cervical ectopy. Race is independently associated with chlamydia infection. Even in populations without these risk factors, however, prevalence rates greater than 5% can occur.

## Diagnostic Tests

Culture analysis of endocervical or urethral swab specimens was traditionally considered the diagnostic gold standard for chlamydial infection. Culture technology posed methodologic shortcomings, however, including variable and often low sensitivity, high expense, limited availability, need for careful handling, a wait of 3 to 5 days for results, and the need for invasive sampling. Nonculture tests with swab specimens were developed next to improve on some of the limitations of culture. These tests initially included antigen-detection tests (direct fluorescent antibody [DFA] assay and enzyme immunoassay [EIA]) and nonamplified nucleic acid hybridization. Newer technologies are based on amplified DNA assays, polymerase chain reaction (PCR) and ligase chain reaction (LCR), and transcription-mediated amplification (TMA) of RNA. Nonculture tests offer advantages of sometimes improved sensitivity, less expense, wider availability, less handling requirements, and timely results. However, these tests still require pelvic examinations for women and urethral swabs for men to obtain specimens. Self-administered vaginal and vulval-introital swabs with PCR and LCR are beginning to be used, and the feasibility of submitting these samples by mail is being tested. The American College of Obstetricians and Gynecologists (ACOG) considers culture a preferred and more sensitive and specific test than the antigen-detection tests.^ 14 ^ ACOG recognizes that the amplification tests may be superior than the culture, but believes they require more clinical evaluation.^ 14 ^

New tests using urine provide a more acceptable method of noninvasive specimen collection for both men and women. Several techniques are available, including antigen-detection tests (EIA, DFA) similar to those used in swab specimens, as well as the new DNA and RNA amplification tests (PCR, LCR, TMA). However, the antigen-detection urine tests are not in wide use and are considered to perform poorly compared with PCR, LCR, and TMA. A disadvantage of the amplification tests is that chlamydia DNA can be detected up to 21 days after treatment because of the presence of nonviable organisms, possibly affecting test of cure or reinfection rates.^ 15 ^ A detailed review of these new diagnostic tests is presented in the Results section of this report.

## Recommendations of the Previous Task Force and Other Groups

### Nonpregnant Women

The second Task Force recommended routine screening during pelvic examination for all sexually active female adolescents and other asymptomatic women at high risk of infection.^ 1 ^ Risk depends on the number of risk factors and local epidemiology of chlamydial infection. Endocervical specimens for cell culture or for nonculture assays were recommended. The optimal frequency of screening was uncertain and unspecified. Routine screening of women in the general population of low-risk adults was not recommended.

The Canadian Task Force on Preventive Health Care recommends that all members of high-risk groups be screened for asymptomatic chlamydial infection.^ 16 ^ The Centers for Disease Control and Prevention (CDC) 1993 recommendations advise routine annual screening for sexually active adolescents younger than 20 years of age, and suggest screening for women 20 to 24 years of age, particularly for those who have new or multiple sex partners and who do not consistently use barrier contraceptives.^ 6 ^ ACOG advises that routine screening is not recommended for all women but should be done for any patient who has risk factors.^ 14 ^ The National Committee for Quality Assurance (NCQA) has added annual chlamydia screening for sexually active women between 15 and 24 years of age to the Health Plan Employer Data and Information Set.^ 17 ^

The CDC 1998 STD treatment guidelines recommend either a single dose of azithromycin or a 7-day course of twice-daily doxycycline, acknowledging that single-dose therapy is preferred when compliance is an issue.^ 18 ^ Ofloxacin is considered as efficacious as azithromycin or doxycycline, but it is more expensive and, according to the CDC, offers no advantage except as an alternative regimen.

### Pregnant Women

The second Task Force recommendations included screening pregnant women at high risk of infection (including women younger than 25 years of age).^ 1 ^ There was insufficient evidence to recommend for or against screening all women during pregnancy. The optimal timing of screening in pregnancy was uncertain and unspecified.

The Canadian Task Force recommends that all pregnant women be screened for chlamydial infection.^ 16 ^ The CDC 1993 recommendations advise screening high-risk women during their third trimester of pregnancy if screening is done only once during pregnancy.^ 6 ^ The CDC recommends using a test of cure when treating with amoxicillin or erythromycin in pregnancy since these regimens are not as efficacious as doxycycline, which is contraindicated in pregnancy.^ 18 ^ ACOG and the American Academy of Pediatrics (AAP) recommend screening pregnant women based on the women's history and physical examination, and do not recommend routine testing of all pregnant women.^ 19 ^ They recommend that women who are to be tested should be tested at the initial visit or during the third trimester or at both these instances and that partners should also be treated.

### Men

The second Task Force stated that there was insufficient evidence to recommend screening in asymptomatic men, but the Task Force recommended screening for selected high-risk male adolescents on other grounds.^ 1 ^ Choice of screening test was left to clinical discretion. The optimal frequency of screening was uncertain and unspecified. Routine screening of men in the general population of low-risk adults was not recommended.

The Canadian Task Force recommends that members of high-risk groups be screened for asymptomatic chlamydial infection.^ 16 ^ The CDC 1993 recommendations advise routine annual screening for sexually active adolescents younger than 20 years of age.^ 6 ^ Neither group further addresses screening in men specifically.

## Analytic Framework and Key Questions

The analytic framework in Figure 1 indicates the strategy we used to guide our literature search for screening in nonpregnant women, pregnant women, and men, respectively. The accompanying key questions (Figure 2) correspond to selected numbered arrows in the analytic framework. Key questions were identified as areas with unresolved issues pertinent to clinical practice that had new literature since the last Task Force recommendations were published in 1996. Key questions were determined in conjunction with liaisons from the USPSTF. The key questions guided our literature review and are addressed in this report (see Chapter 3, “Results”).

Figure 1. Screening for chlamydial infection—analytic framework

The analytic framework shows the target populations, interventions, intermediate outcome measures, and health outcome measures we examined. After a preliminary search of the literature, we decided to focus on evidence of the effectiveness of screening strategies in nonpregnant women, pregnant women, and men; the accuracy of tests used for screening; as well as evidence that early treatment of chlamydial infection improves health outcomes. Although the adverse effects of screening are an important component of the analytic framework, they were not reported in the literature. Inconvenience, the social stigma of sexually transmitted diseases, possible discord and exacerbation of domestic violence among sexual partners, and concern related to testing errors were among the adverse effects we explored in the literature.

We defined screening to include testing in asymptomatic persons and casefinding in those found to have another sexually transmitted infection. Universal screening means that everyone is tested, regardless of symptoms or risk factors; selective screening indicates that only those who meet specific criteria are tested.