# Appendix 3: Chlamydia Cost Studies Search Terms

The topic of chlamydia cost studies was searched in the MEDLINE database from January 1989 to November 1999. The search included all languages and was not limited to humans since an article on this topic could discuss just the economic effect of the disease without actually mentioning the patient.

1. exp chlamydia infections
  - conjunctivitis, inclusion
  - lymphogranuloma venereum
  - ornithosis
  - trachoma
2. exp costs and cost analysis
  - cost allocation
  - cost-benefit analysis
  - cost control
  - cost of illness
  - cost sharing
  - health care costs
  - health expenditures
3. 1 and 2
4. exp chlamydia infections/ec
  - subheading ec=economics
5. 3 or 4