# Appendix 2: Chlamydia Search Terms

The topic of chlamydia was searched in the MEDLINE and HealthStar databases from January 1994 to November 1999.

1. exp chlamydia infections
  - conjunctivitis, inclusion
  - lymphogranuloma venereum
  - ornithosis
  - trachoma
2. exp mass screening
  - genetic screening
  - mass chest x-ray
  - multiphasic screening
  - vision screening
  - mandatory testing
3. screen$.tw. (Text word taken from title and abstract of article)
4. 2 or 3
5. 1 and 4
6. exp clinical trials
  - clinical trials, phases 1 through 4
  - controlled clinical trials
  - multicenter studies
  - randomized controlled trials
7. meta-analysis
8. evidence-based medicine
9. 6 or 7 or 8
10. 1 and 9
11. 5 or 10
12. limit 1 to clinical trials, RCT, meta-analysis and controlled clinical trials (as a publication type)
13. 11 or 12
14. endometritis
15. exp adnexitis
  - oophoritis
  - parametritis
  - salpingitis
16. urethritis
17. cervicitis
18. epididymitis
19. infant, newborn
20. infant, premature
21. 14 or 15 or 16 or 17 or 18 or 19 or 20
22. 1 and 21
23. 13 or 22
24. exp *chlamydia infections/di/dt/th (diagnosis or drug therapy or other therapies)
25. 23 or 24
26. limit 25 to human
27. limit 26 to English language
28. looked at English abstracts of foreign language articles