# Appendix 1: Evidence Tables

Evidence Table 1. Chlamydia Screening Programs and Prevalence for WomenAppendix 1: Evidence Tables

Author/Year | Design | N | Population/Setting | Screening Program | Test | Prevalence Rates (%)
Mosure et al^ 26 ^/1997 | Retrospective cohort | 148,650 | Sexually active 15-19 year olds undergoing pelvic exams during 1988-1992 in 160 family planning clinics in 4 NW US states (Region X) | Universal testing in conjunction with pelvic exam | Endocervical | 1988—13.2%
Mosure et al^ 26 ^/1997 | Retrospective cohort | 148,650 | Sexually active 15-19 year olds undergoing pelvic exams during 1988-1992 in 160 family planning clinics in 4 NW US states (Region X) | Universal testing in conjunction with pelvic exam | DFA | 1992—7.6%
Herrmann et al^ 27 ^/1995 | Prospective | 119,892 79% female | Men and women who sought care in Swedish health clinics for any reason and who were screened for chlamydia during 1985-1993 | National legislation in 1988 encouraged screening; new youth clinics opened, contact tracing expanded, increased health education for youth; exam and treatment free; women offered exam with routine care; men usually came with symptoms or from contacts | 86% culture 14% EIA | Women:
Herrmann et al^ 27 ^/1995 | Prospective | 119,892 79% female | Men and women who sought care in Swedish health clinics for any reason and who were screened for chlamydia during 1985-1993 | | 86% culture 14% EIA | 1985—10.7%
Herrmann et al^ 27 ^/1995 | Prospective | 119,892 79% female | Men and women who sought care in Swedish health clinics for any reason and who were screened for chlamydia during 1985-1993 | | 86% culture 14% EIA | 1993—3.2%
Herrmann et al^ 27 ^/1995 | Prospective | 119,892 79% female | Men and women who sought care in Swedish health clinics for any reason and who were screened for chlamydia during 1985-1993 | | 86% culture 14% EIA | Men:
Herrmann et al^ 27 ^/1995 | Prospective | 119,892 79% female | Men and women who sought care in Swedish health clinics for any reason and who were screened for chlamydia during 1985-1993 | | 86% culture 14% EIA | 1985—18.3%
Herrmann et al^ 27 ^/1995 | Prospective | 119,892 79% female | Men and women who sought care in Swedish health clinics for any reason and who were screened for chlamydia during 1985-1993 | | 86% culture 14% EIA | 1993—7.1%
Herrmann et al^ 27 ^/1995 | Prospective | 119,892 79% female | Men and women who sought care in Swedish health clinics for any reason and who were screened for chlamydia during 1985-1993 | | 86% culture 14% EIA | Rates remained high in adolescent populations
Cleavenger et al^ 28 ^/1996 | Prospective | 36,582 | Male and female students seeking care in a university health service in West Virginia during 1989-1994 | Universal testing with routine pelvic exams, counseling about STD prevention, free condoms | Endocervical EIA | Men and women:
Cleavenger et al^ 28 ^/1996 | Prospective | 36,582 | Male and female students seeking care in a university health service in West Virginia during 1989-1994 | Universal testing with routine pelvic exams, counseling about STD prevention, free condoms | Endocervical EIA | 1989—8.8%
Cleavenger et al^ 28 ^/1996 | Prospective | 36,582 | Male and female students seeking care in a university health service in West Virginia during 1989-1994 | Universal testing with routine pelvic exams, counseling about STD prevention, free condoms | Endocervical EIA | 1994—3.5%
Cleavenger et al^ 28 ^/1996 | Prospective | 36,582 | Male and female students seeking care in a university health service in West Virginia during 1989-1994 | Universal testing with routine pelvic exams, counseling about STD prevention, free condoms | Endocervical EIA | 1028 cases for women
Cleavenger et al^ 28 ^/1996 | Prospective | 36,582 | Male and female students seeking care in a university health service in West Virginia during 1989-1994 | Universal testing with routine pelvic exams, counseling about STD prevention, free condoms | Endocervical EIA | 178 cases for men
Crowley et al^ 29 ^/1994 | Prospective | 23,174 | Men and women who presented to genitourinary clinics in the UK with a new problem during 1988-1993 | Universal testing for those who had a new problem; careful follow up and recall for treatment of positives; contacts traced, tested, and treated | EIA confirmed by DIF | Women:
Crowley et al^ 29 ^/1994 | Prospective | 23,174 | Men and women who presented to genitourinary clinics in the UK with a new problem during 1988-1993 | Universal testing for those who had a new problem; careful follow up and recall for treatment of positives; contacts traced, tested, and treated | EIA confirmed by DIF | 1989—12.1%
Crowley et al^ 29 ^/1994 | Prospective | 23,174 | Men and women who presented to genitourinary clinics in the UK with a new problem during 1988-1993 | Universal testing for those who had a new problem; careful follow up and recall for treatment of positives; contacts traced, tested, and treated | EIA confirmed by DIF | 1993—6.6%
Crowley et al^ 29 ^/1994 | Prospective | 23,174 | Men and women who presented to genitourinary clinics in the UK with a new problem during 1988-1993 | Universal testing for those who had a new problem; careful follow up and recall for treatment of positives; contacts traced, tested, and treated | EIA confirmed by DIF | Trend P<0.00001
van Duynhoven et al^ 30 ^/1995 | Prospective | 1,595 41% female | Men and women who presented to STD clinic in Amsterdam during 1986-1993 | Testing strategy was implemented in 1989: universal for females and for males who had urethritis | Culture females; EIA and culture males | Women:
van Duynhoven et al^ 30 ^/1995 | Prospective | 1,595 41% female | Men and women who presented to STD clinic in Amsterdam during 1986-1993 | Testing strategy was implemented in 1989: universal for females and for males who had urethritis | Culture females; EIA and culture males | 1986-1988—21.5%
van Duynhoven et al^ 30 ^/1995 | Prospective | 1,595 41% female | Men and women who presented to STD clinic in Amsterdam during 1986-1993 | Testing strategy was implemented in 1989: universal for females and for males who had urethritis | Culture females; EIA and culture males | 1993—7.3%
van Duynhoven et al^ 30 ^/1995 | Prospective | 1,595 41% female | Men and women who presented to STD clinic in Amsterdam during 1986-1993 | Testing strategy was implemented in 1989: universal for females and for males who had urethritis | Culture females; EIA and culture males | Men:
van Duynhoven et al^ 30 ^/1995 | Prospective | 1,595 41% female | Men and women who presented to STD clinic in Amsterdam during 1986-1993 | Testing strategy was implemented in 1989: universal for females and for males who had urethritis | Culture females; EIA and culture males | 1986-1988—15.8%
van Duynhoven et al^ 30 ^/1995 | Prospective | 1,595 41% female | Men and women who presented to STD clinic in Amsterdam during 1986-1993 | Testing strategy was implemented in 1989: universal for females and for males who had urethritis | Culture females; EIA and culture males | 1993—7.5%
Katz et al^ 31 ^/1996 | Prospective | 4,329 | Sexually active females 13-19 years of age, attending 4 adolescent health clinics in Indianapolis during 1985-1994 | Universal testing, behavioral counseling, contact tracing | Endocervical culture | 1985— 25.9%
Katz et al^ 31 ^/1996 | Prospective | 4,329 | Sexually active females 13-19 years of age, attending 4 adolescent health clinics in Indianapolis during 1985-1994 | Universal testing, behavioral counseling, contact tracing | Endocervical culture | 1994—9.7%
Katz et al^ 31 ^/1996 | Prospective | 4,329 | Sexually active females 13-19 years of age, attending 4 adolescent health clinics in Indianapolis during 1985-1994 | Universal testing, behavioral counseling, contact tracing | Endocervical culture | Trend P<0.0001 First-visit data only
Mertz et al^ 33 ^/1997 | Cross-sectional | 197,738 | Women 15-44 years of age tested for chlamydia at more than 50 sites in Ohio during 1989-1992 | Universal testing of women receiving pelvic exams | Endocervical EIA and DNA probe | 1989—8.0%
Mertz et al^ 33 ^/1997 | Cross-sectional | 197,738 | Women 15-44 years of age tested for chlamydia at more than 50 sites in Ohio during 1989-1992 | Universal testing of women receiving pelvic exams | Endocervical EIA and DNA probe | 1992—5.4%
Mertz et al^ 33 ^/1997 | Cross-sectional | 197,738 | Women 15-44 years of age tested for chlamydia at more than 50 sites in Ohio during 1989-1992 | Universal testing of women receiving pelvic exams | Endocervical EIA and DNA probe | Less effect on rates for black women

DFA, direct flluorescent antibody; EIA, enzyme immunoassay; DIF, direct immunofluorescence

Evidence Table 2. Risk factors for women—studies published since 1994Appendix 1: Evidence Tables

Author/Year | Design | N | Population | Setting | Criteria | Test
Gaydos et al^ 34 ^/1998 | Cross-sectional | 13,204 | New U.S. Army recruits from 50 states All asymptomatic | Army medical facility | Universal | Urine LCR; risk-factor survey
Mosure et al^ 35 ^/1996 Mosure et al^ 26 ^/1997 | Retrospectivecohort | 28,000 | Sexually active 15-19 year olds screenedduring pelvic exams | 160 family planning clinics 4 NW U.S. states (Region X) | Universal | Endocervical DFA; questionnaire
Finelli et al^ 36 ^/1996 | Cross-sectional | 5,128 | 12-29 year olds who presented for routine gynecologic exams or urogenital complaints | 15 public clinics (5 STD, 5 family plan-ning, 5 college clinics) New Jersey | Universal | Endocervical EIA; questionnaire
Bontis et al^ 37 ^/1994 | Cross-sectional | 400 | 18-45 year olds who attended Ob/Gyn clinics and family planning clinics for routine exams | Clinics Greece | Universal | Endocervical EIA; survey

Evidence Table 3. Chlamydia screening tests forwomen—studies published since 1994Appendix 1: Evidence Tables

Author/Year | Test(s) | Specimen | Gold Standard | Specimen | Discrepant Test (DT) | Specimen | Expanded Gold Standard | Ref #
Chout et al^ 48 ^/1995 | PCR (Amplicor) | Cervical swab | Culture | Cervical swab | PCR-MOMP and a second plasmid-based PCR | Cervical swab | Positive: confirmed + | 104.00
Lisby et al^ 49 ^/1994 | PCR (Amplicor) EIA | Cervical or urethral swabs | None | | DFA and PCR-MOMP | Cervical or urethral swabs | Positive: confirmed + | 255.00
Skulnick et al^ 50 ^/1994 | PCR (Amplicor) | Cervical swab and FVU | Culture | Cervical swab | PCR then PCR-MOMP for confirmation | Cervical swab or FVU | Positive: culture+ and/or PCR+/PCR-MOMP+ | 136.00
| EIA (MicroTrak II) | Cervical swab
Davis et al^ 51 ^/1998 | PCR (Amplicor) | Cervical swab | None | | Repeat testing then PCR-MOMP for confirmation | Cervical swab | Positive: repeat test+ and/or PCR-MOMP+ | 4.00
Davis et al^ 51 ^/1998 | LCR | Cervical swab | None | | Repeat testing then PCR-MOMP for confirmation | Cervical swab | Positive: repeat test+ and/or PCR-MOMP+ | 4.00
Gaydos et al^ 52 ^/1998 | LCR | FVU | Culture | Cervical swab | DFA, PCR, LCR-MOMP | Cervical swab FVU | Positive: culture+ or LCR+ with discrepant test+ | 272.00
van Doornum et al^ 53 ^/1995 | LCR | FVU | Culture | Cervical swab | Repeat LCR and LCR-MOMP | FVU | Positive: culture+ or LCR+/LCR-MOMP+
Ossewaarde et al^ 54 ^/1997 | PCR (Amplicor) | Cervical swab | EIA | Cervical swab | PCR-MOMP | Cervical swab | Positive: PCR+/EIA+or PCR+MOMP- | 113.00
Ossewaarde et al^ 54 ^/1997 | PACE 2 (Vienna only) | Cervical swab | EIA | Cervical swab | PCR-MOMP | Cervical swab | Positive: PCR+/EIA+or PCR+MOMP- | 113.00
Crotchfelt et al^ 55 ^/1997 | PCR | FVU, Cervical swab | Culture | Cervical swab | DFA and PCR-MOMP | FVU | Positive: culture+ or PCR+/DFA+ or PCR-MOMP+ | 126.00
Hallsworth et al^ 56 ^/1995 | PCR (in-house) | Cervical swab | Culture | Cervical swab | None | | Positive: culture+ or 2 nonculture+ results | 255.00
Hallsworth et al^ 56 ^/1995 | DFA | Cervical swab | Culture | Cervical swab | None | | Positive: culture+ or 2 nonculture+ results | 255.00
Quinn et al^ 57 ^/1996 | PCR (Amplicor) | FVU | Culture | Cervical swab | DFA and PCR-MOMP | Cervical swab | Positive: culture+ or DFA+/PCR-MOMP+ | 180.00
Quinn et al^ 57 ^/1996 | PCR | Cervical swab | Culture | Cervical swab | DFA and PCR-MOMP | Cervical swab | Positive: culture+ or DFA+/PCR-MOMP+ | 180.00
Toye et al^ 58 ^/1996 | PCR | Cervical swab | Culture | Cervical swab | PCR-MOMP | Cervical swab | Positive: culture+ or PCR+/PCR-MOMP+ | 181.00

Evidence Table 4. Prevalence and risk factors for chlamydia in men—studies published since 1994Appendix 1: Evidence Tables

Author/Year | Design | N | Population | Setting | Tests | Prev(%) | Independent Associations
Oh et al^ 104 ^/1994 | Cross sectional | 957 | Adolescents in detention Median age 16 (range 11-18) 86% black 5% symptomatic | Youth detention center Birmingham, AL | Culture | 6.9 | None
Quinn et al^ 57 ^/1996 | Cross sectional | 471 | Median age 26 (range 16-60) 96% black 56% symptomatic | 2 STD clinics Baltimore, Md | PCR (FVU) | 14.2 | Not reported
Quinn et al^ 57 ^/1996 | Cross sectional | 471 | Median age 26 (range 16-60) 96% black 56% symptomatic | 2 STD clinics Baltimore, Md | Culture | 8.5 | Not reported
Lafferty et al^ 103 ^/1997 | Cross sectional | 1,253 | Men who have sex with men Mean age 31.7 (range 16-80) 9.3% black, 76.6% white, 6.2% Hispanic | STD clinic Seattle, Wash | Culture | 2.5 | Not reported
Sessaet al^ 45 ^/1994 | Cross sectional | 1,631 | 14% <=25 years old | Urogenital clinics at 3 hospitals Italy | EIA (swab) | 9.8 | Highest rates for age<25 (20.9%) Rates increase with symptoms
Sessaet al^ 45 ^/1994 | Cross sectional | 1,631 | 60% asymptomatic | Urogenital clinics at 3 hospitals Italy | EIA (swab) | 9.8 | Highest rates for age<25 (20.9%) Rates increase with symptoms
Marrazzoet al^ 102 ^/ 1997 | Cross sectional | 5,150 | >=11 years old Median age 16 98.6% asymptomatic | Multisite: adolescent primary care clinic, juvenile detention facility, secondary school health clinics, community-based organizations providing social services to homeless youth Seattle, Wash | LCR (FVU) | 5.4 | Nonwhite race or ethnicity (OR, 2.00-3.08) > 2 partners in previous 2 mo (OR, 1.57) Used a condom (OR, 0.67) Symptoms (OR, 6.09) Odds increase with age (P<0.001 for trend)
Urban et al^ 107 ^/1997 | Cross sectional | 9,552 | 10% <20 years old, 45% 20-30 years old45% >30 years old 52% black | STD clinic Rochester, NY | DFA (swab)b) | 4.7 | Infection more likely in black men and men <24 years old 63% of cases were symptomatic
Gunn et al^ 105 ^/1998 | Cross sectional | 261 | Teenagers >85% black or Hispanic 86% refusal rate | Community outreach in high-risk STD transmission area San Diego, Calif | PCR (FVU) | 6.1 | Not reported
Oh et al^ 81 ^/1998 | Cross sectional | 217 | Adolescents in detention Mean age 15.7 (range 12-18) 83% black All asymptomatic | Youth detention center Birmingham, Ala | LCR (FVU) | 8.8 | Not reported
van Duynhovenet al^ 30 ^/1995 | Cross sectional | 947 | Heterosexual men Mean age 32 (range 14-74) 38% with discharge | STD clinic; 1986-1988 Amsterdam, Netherlands | Culture | 15.8 | <26 years old (OR,1.59)
van Duynhovenet al^ 30 ^/1995 | Cross sectional | 947 | Heterosexual men Mean age 32 (range 14-74) 38% with discharge | STD clinic; 1986-1988 Amsterdam, Netherlands | Culture | 15.8 | Sexual activity <13 years old (OR, 2.50)
van Duynhovenet al^ 30 ^/1995 | Cross sectional | 947 | Heterosexual men Mean age 32 (range 14-74) 38% with discharge | STD clinic; 1986-1988 Amsterdam, Netherlands | Culture | 15.8 | STD in partner (OR, 2.53)
van Duynhovenet al^ 30 ^/1995 | Cross sectional | 947 | Heterosexual men Mean age 32 (range 14-74) 38% with discharge | STD clinic; 1986-1988 Amsterdam, Netherlands | Culture | 15.8 | Last contact was a prostitute (OR, 0.48)
van Duynhovenet al^ 30 ^/1995 | Cross sectional | 947 | Heterosexual men Mean age 32 (range 14-74) 38% with discharge | STD clinic; 1986-1988 Amsterdam, Netherlands | Culture | 15.8 | Urethral discharge (OR>2.00)
Poulinet al^ 106 ^/1997 | Cross sectional | 211 | Adolescents in detention 18 years old or younger | Youth detention center Montreal, Canada | EIA (swab and FVU) | 3.0 | Not reported
Orr et al^ 88 ^/1994 | Retrospective review | 17,270 | Residents of Manitoba | Laboratory data from tests for C trachomatisCanada | DFA, EIA confirmed by antigen and/or cult | 12.4 | Not reported
Harry et al^ 108 ^/1994 | Retrospective review | 1,318 | Men attending genitourinary medicine clinic Mean age 24.6 (range 17-46) for positive chlamydia cases 21% asymptomatic | Genitourinary medicine clinic UK | EIA (swab) | 6.8 | Not reported
Herrmann and Egger^ 27 ^/1995 | Retrospective review | 25,177 | Men examined for suspected chlamydial infection, 1985-1993 Mean age 26.5-27.4 | Data from national laboratory service: 1 STD clinic, 6 youth clinics, 5 gyn clinics, 3 family planning clinics, 14 antenatal clinics, 34 primary clinics, 15-20 private practices Sweden | 86% culture 14% EIA (swab) | 7.1-18.3 | Higher OR among younger men: 15-19 (OR, 2.63) 20-24 (OR, 2.66) 25-29 (OR, 1.85) >29 (OR, 1.00) Prevalence declined over time (1985-1993)
British CCG^ 109 ^/1997 | Survey of GU consults | 30,402 | Patients attending GU medicine clinics for infection 11% <20 years old | 76 genitourinary clinics UK (70% response rate) | Not given | 4.6 | 16-19 years old (RR, 2.85; 1.58-5.16)

STD, sexually transmitted disease; PCR, polymerase chain reaction; FVU, first void urine; EIA, enzyme immunoassay; LCR, ligasechain reaction; OR, odds ratio;

DFA, direct fluorescent antibody; GU, genitourinary; RR, relative risk.

Evidence Table 5. Chlamydia screening tests for men—studies published since 1994Appendix 1: Evidence Tables

Author/Year | Test(s) | Specimen | Gold Standard | Specimen | Discrepant Test (DT) | Specimen | Expanded Gold Standard | #Men | Symptoms | Population | Prevalence | Test | Summary of Results | | PPV | NPV
Author/Year | Test(s) | Specimen | Gold Standard | Specimen | Discrepant Test (DT) | Specimen | Expanded Gold Standard | #Men | Symptoms | Population | Prevalence | Test | Sensitivity | Spcificity | PPV | NPV
Higgins et al^ 113 ^/1998 | PCR (Amplicor) | FVU, swab | Radioimmune dot blot (DB) | Swab | PCR-MOMP | FVU | Positive: confirmed + | 379 | Proportion not reported | STD clinic Manchester, UK | 13.3% by PCR (FVU) | PCR (FVU) | 0.87 | 1.00
Higgins et al^ 113 ^/1998 | PCR (Amplicor) | FVU, swab | Radioimmune dot blot (DB) | Swab | PCR-MOMP | FVU | Positive: confirmed + | 379 | Proportion not reported | STD clinic Manchester, UK | 13.8% by PCR (swab) | PCR (swab) | 0.90 | 1.00
Higgins et al^ 113 ^/1998 | PCR (Amplicor) | FVU, swab | Radioimmune dot blot (DB) | Swab | PCR-MOMP | FVU | Positive: confirmed + | 379 | Proportion not reported | STD clinic Manchester, UK | 8.5% by DB (swab) | DB (swab) | 0.55
Hallsworth et al^ 56 ^/1995 | PCR (in-house) DIF | FVU, swab FVU, swab | Culture | Swab | None | | Positive: culture+ or 2 nonculture+ results | 296 | One or more factors: Urethral discharge/dysuria Sex contact with known case Age less than 20 years | Central STD clinic Adelaide, Australia | 9.1% by PCR/DIF/culture (swab) 18.8% by PCR/DIF (FVU) | PCR (swab) | 1.00 | 1.00
Hallsworth et al^ 56 ^/1995 | PCR (in-house) DIF | FVU, swab FVU, swab | Culture | Swab | None | | Positive: culture+ or 2 nonculture+ results | 296 | One or more factors: Urethral discharge/dysuria Sex contact with known case Age less than 20 years | Central STD clinic Adelaide, Australia | 9.1% by PCR/DIF/culture (swab) 18.8% by PCR/DIF (FVU) | PCR (FVU) | 0.76 | 1.00
Hallsworth et al^ 56 ^/1995 | PCR (in-house) DIF | FVU, swab FVU, swab | Culture | Swab | None | | Positive: culture+ or 2 nonculture+ results | 296 | One or more factors: Urethral discharge/dysuria Sex contact with known case Age less than 20 years | Central STD clinic Adelaide, Australia | 9.1% by PCR/DIF/culture (swab) 18.8% by PCR/DIF (FVU) | DIF (swab) | 0.85 | 1.00
Hallsworth et al^ 56 ^/1995 | PCR (in-house) DIF | FVU, swab FVU, swab | Culture | Swab | None | | Positive: culture+ or 2 nonculture+ results | 296 | One or more factors: Urethral discharge/dysuria Sex contact with known case Age less than 20 years | Central STD clinic Adelaide, Australia | 9.1% by PCR/DIF/culture (swab) 18.8% by PCR/DIF (FVU) | DIF (FVU) | 0.71 | 1.00
Hallsworth et al^ 56 ^/1995 | PCR (in-house) DIF | FVU, swab FVU, swab | Culture | Swab | None | | Positive: culture+ or 2 nonculture+ results | 296 | One or more factors: Urethral discharge/dysuria Sex contact with known case Age less than 20 years | Central STD clinic Adelaide, Australia | 9.1% by PCR/DIF/culture (swab) 18.8% by PCR/DIF (FVU) | Culture | 0.96 | 1.00
Domeika et al^ 114 ^/1994 | PCR (Amplicor) EIA (Syva) | FVU FVU | None | | PCR-MOMP | FVU | Positive: PCR+ /EIA+ or PCR+ or EIA+/PCR-MOMP+ | 184 | All asymptomatic | Skin and STD clinic Sweden Men presenting for non-STD reasons Mean age 32 | 18.5% by both EIA and PCR | PCR (FVU) | 1.00 | 1.00 | 1.00 | 1.00
Domeika et al^ 114 ^/1994 | PCR (Amplicor) EIA (Syva) | FVU FVU | None | | PCR-MOMP | FVU | Positive: PCR+ /EIA+ or PCR+ or EIA+/PCR-MOMP+ | 184 | All asymptomatic | Skin and STD clinic Sweden Men presenting for non-STD reasons Mean age 32 | 18.5% by both EIA and PCR | EIA (FVU) | 0.85 | 1.00 | 1.00 | 0.78
Noren et al^ 115 ^/1998 | PCR (Amplicor) EIA (Micro Trak) | FVU FVU | Culture | Swab | PCR then PCR-MOMP for confirmation | FVU | Positive: culture+ or PCR+/PCR-MOMP+ | 467 | Proportion not reported | STD clinic and 2 other asymptomatic populations, including military including military Average age 27 Stockholm, Sweden | 9.9% by PCR 7.9% by EIA | PCR (FVU) | 1.00 | 1.00 | 1.00 | 1.00
Noren et al^ 115 ^/1998 | PCR (Amplicor) EIA (Micro Trak) | FVU FVU | Culture | Swab | PCR then PCR-MOMP for confirmation | FVU | Positive: culture+ or PCR+/PCR-MOMP+ | 467 | Proportion not reported | STD clinic and 2 other asymptomatic populations, including military including military Average age 27 Stockholm, Sweden | 9.9% by PCR 7.9% by EIA | EIA (FVU) | 0.80 | 1.00 | 1.00 | 0.98
Wiesenfeld et al^ 116 ^/1995 | PCR | FVU, swab | EIA (Chlamydiazyme) | Swab | PCR then PCR-MOMP for confirmation | FVU | Positive: PCR+/EIA+ or EIA-/PCR+/PCR+MOMP- | 474 (swab) 362 (FVU) | Proportion not reported | STD clinic, county health department Pittsburgh, PA | 13.5% by PCR 5.7% by EIA | PCR (swab) | 0.98 | 0.99 | 0.94 | 1.00
Wiesenfeld et al^ 116 ^/1995 | PCR | FVU, swab | EIA (Chlamydiazyme) | Swab | PCR then PCR-MOMP for confirmation | FVU | Positive: PCR+/EIA+ or EIA-/PCR+/PCR+MOMP- | 474 (swab) 362 (FVU) | Proportion not reported | STD clinic, county health department Pittsburgh, PA | 13.5% by PCR 5.7% by EIA | PCR (FVU) | 0.87 | 0.98 | 0.90 | 0.97
Wiesenfeld et al^ 116 ^/1995 | PCR | FVU, swab | EIA (Chlamydiazyme) | Swab | PCR then PCR-MOMP for confirmation | FVU | Positive: PCR+/EIA+ or EIA-/PCR+/PCR+MOMP- | 474 (swab) 362 (FVU) | Proportion not reported | STD clinic, county health department Pittsburgh, PA | 13.5% by PCR 5.7% by EIA | EIA (swab) | 0.44 | 1.00 | 1.00 | 0.92
Quinn et al^ 57 ^/1996 | PCR (Amplicor) | FVU | Culture | Swab | DFA and PCR-MOMP | FVU | Positive: culture+ or DFA+/PCR-MOMP+ | 713 | 86% symptomatic | STD clinic Baltimore, Md 96% African American Mean age 23 | 5.3% by culture 10.5% by culture and PCR | Culture | 0.51 | 1.00 | 1.00 | 0.95
Quinn et al^ 57 ^/1996 | PCR (Amplicor) | FVU | Culture | Swab | DFA and PCR-MOMP | FVU | Positive: culture+ or DFA+/PCR-MOMP+ | 713 | 86% symptomatic | STD clinic Baltimore, Md 96% African American Mean age 23 | 5.3% by culture 10.5% by culture and PCR | PCR (FVU) | 0.88 | 0.97 | 0.88 | 0.99
Ossewaarde et al^ 54 ^/1997 | PCR (Amplicor) PACE 2 (Vienna only) | FVU Swab | EIA (Chlamydiazyme) | Swab | PCR-MOMP | FVU | Positive: PCR+/EIA+ or PCR+MOMP- | 270 (A) 344 (V) | Proportion not reported | STD clinic Amsterdam and Vienna | 13.7% (Amsterdam) 10.8% (Vienna) | A: PCR (FVU) | 0.95 | 0.98 | 0.90 | 0.99
Ossewaarde et al^ 54 ^/1997 | PCR (Amplicor) PACE 2 (Vienna only) | FVU Swab | EIA (Chlamydiazyme) | Swab | PCR-MOMP | FVU | Positive: PCR+/EIA+ or PCR+MOMP- | 270 (A) 344 (V) | Proportion not reported | STD clinic Amsterdam and Vienna | 13.7% (Amsterdam) 10.8% (Vienna) | A: PCR (swab) | 0.65 | 0.98 | 0.83 | 0.95
Ossewaarde et al^ 54 ^/1997 | PCR (Amplicor) PACE 2 (Vienna only) | FVU Swab | EIA (Chlamydiazyme) | Swab | PCR-MOMP | FVU | Positive: PCR+/EIA+ or PCR+MOMP- | 270 (A) 344 (V) | Proportion not reported | STD clinic Amsterdam and Vienna | 13.7% (Amsterdam) 10.8% (Vienna) | A: EIA (swab) | 0.60 | 1.00 | 1.00 | 0.94
Ossewaarde et al^ 54 ^/1997 | PCR (Amplicor) PACE 2 (Vienna only) | FVU Swab | EIA (Chlamydiazyme) | Swab | PCR-MOMP | FVU | Positive: PCR+/EIA+ or PCR+MOMP- | 270 (A) 344 (V) | Proportion not reported | STD clinic Amsterdam and Vienna | 13.7% (Amsterdam) 10.8% (Vienna) | V: PCR (FVU) | 0.46 | 0.97 | 0.65 | 0.94
Ossewaarde et al^ 54 ^/1997 | PCR (Amplicor) PACE 2 (Vienna only) | FVU Swab | EIA (Chlamydiazyme) | Swab | PCR-MOMP | FVU | Positive: PCR+/EIA+ or PCR+MOMP- | 270 (A) 344 (V) | Proportion not reported | STD clinic Amsterdam and Vienna | 13.7% (Amsterdam) 10.8% (Vienna) | V : PCR (swab) | 0.70 | 0.99 | 0.90 | 0.97
Ossewaarde et al^ 54 ^/1997 | PCR (Amplicor) PACE 2 (Vienna only) | FVU Swab | EIA (Chlamydiazyme) | Swab | PCR-MOMP | FVU | Positive: PCR+/EIA+ or PCR+MOMP- | 270 (A) 344 (V) | Proportion not reported | STD clinic Amsterdam and Vienna | 13.7% (Amsterdam) 10.8% (Vienna) | V: EIA (swab) | 0.70 | 1.00 | 1.00 | 0.97
Ossewaarde et al^ 54 ^/1997 | PCR (Amplicor) PACE 2 (Vienna only) | FVU Swab | EIA (Chlamydiazyme) | Swab | PCR-MOMP | FVU | Positive: PCR+/EIA+ or PCR+MOMP- | 270 (A) 344 (V) | Proportion not reported | STD clinic Amsterdam and Vienna | 13.7% (Amsterdam) 10.8% (Vienna) | V: PACE 2 (swab) | 0.65 | 1.00 | 1.00 | 0.96
Crotchfelt et al^ 55 ^/1997 | PCR | FVU, swab | Culture | Swab | DFA and PCR-MOMP | FVU | Positive: culture+ or PCR+/DFA+ or PCR-MOMP+ | 344 | Proportion not reported | STD clinics Baltimore, Md | 13.1% by PCR (FVU) 8.4% by culture 14.8% by PCR (swab) | PCR (FVU) | 0.88 | 0.99 | 0.80 | 0.99
Crotchfelt et al^ 55 ^/1997 | PCR | FVU, swab | Culture | Swab | DFA and PCR-MOMP | FVU | Positive: culture+ or PCR+/DFA+ or PCR-MOMP+ | 344 | Proportion not reported | STD clinics Baltimore, Md | 13.1% by PCR (FVU) 8.4% by culture 14.8% by PCR (swab) | Culture | 0.52 | 1.00 | 0.52 | 1.00
Crotchfelt et al^ 55 ^/1997 | PCR | FVU, swab | Culture | Swab | DFA and PCR-MOMP | FVU | Positive: culture+ or PCR+/DFA+ or PCR-MOMP+ | 344 | Proportion not reported | STD clinics Baltimore, Md | 13.1% by PCR (FVU) 8.4% by culture 14.8% by PCR (swab) | PCR (swab) | 0.96 | 0.99 | 0.91 | 0.99
Toye et al^ 58 ^/1996 | PCR EIA | FVU, swab FVU | Culture | Swab | PCR-MOMP | FVU | Positive: culture+ or PCR+/PCR-MOMP+ | 472 (swab) 379 (FVU) | All asymptomatic | Sexual health center Ottawa, Canada Mean age 27 | 7.6% | Culture | 0.61 | 1.00 | 1.00 | 0.97
Toye et al^ 58 ^/1996 | PCR EIA | FVU, swab FVU | Culture | Swab | PCR-MOMP | FVU | Positive: culture+ or PCR+/PCR-MOMP+ | 472 (swab) 379 (FVU) | All asymptomatic | Sexual health center Ottawa, Canada Mean age 27 | 7.6% | PCR (swab) | 0.72 | 1.00 | 0.96 | 0.98
Toye et al^ 58 ^/1996 | PCR EIA | FVU, swab FVU | Culture | Swab | PCR-MOMP | FVU | Positive: culture+ or PCR+/PCR-MOMP+ | 472 (swab) 379 (FVU) | All asymptomatic | Sexual health center Ottawa, Canada Mean age 27 | 7.6% | PCR (FVU) | 0.91 | 1.00 | 1.00 | 0.99
Toye et al^ 58 ^/1996 | PCR EIA | FVU, swab FVU | Culture | Swab | PCR-MOMP | FVU | Positive: culture+ or PCR+/PCR-MOMP+ | 472 (swab) 379 (FVU) | All asymptomatic | Sexual health center Ottawa, Canada Mean age 27 | 7.6% | EIA (FVU) | 0.55 | 1.00 | 1.00 | 0.97
Chernesky et al^ 117 ^/1997 | LCR PCR DFA | FVU FVU Swab | Culture | Swab | LCR or PCR-MOMP | FVU | Positive: one test+ and MOMP test+ | 287 | 37.6% symptomatic | Hospital-based STD clinic Ontario, Canada | 11.5% by LCR | LCR (FVU) | 0.94 | 1.00 | 0.97 | 0.99
Chernesky et al^ 117 ^/1997 | LCR PCR DFA | FVU FVU Swab | Culture | Swab | LCR or PCR-MOMP | FVU | Positive: one test+ and MOMP test+ | 287 | 37.6% symptomatic | Hospital-based STD clinic Ontario, Canada | 12.2% by PCR | PCR (FVU) | 1.00 | 0.98 | 0.88 | 1.00
Chernesky et al^ 117 ^/1997 | LCR PCR DFA | FVU FVU Swab | Culture | Swab | LCR or PCR-MOMP | FVU | Positive: one test+ and MOMP test+ | 287 | 37.6% symptomatic | Hospital-based STD clinic Ontario, Canada | 4.5% by culture | Culture | 0.37 | 1.00
Chernesky et al^ 117 ^/1997 | LCR PCR DFA | FVU FVU Swab | Culture | Swab | LCR or PCR-MOMP | FVU | Positive: one test+ and MOMP test+ | 287 | 37.6% symptomatic | Hospital-based STD clinic Ontario, Canada | 5.2% by DFA | DFA (FVU) | 0.43 | 1.00
Catry et al^ 62 ^/1995 | PCR (Amplicor) | FVU | Culture | Swab | PCR-MOMP, DFA | FVU | Positive: culture+ or MOMP+/DFA+ | 112 | Proportion not reported | STD clinic Portugal | 6.3% | PCR (FVU) | 1.00 | 0.99 | 1.00 | 0.99
Carroll et al^ 63 ^/1998 | LCR PACE 2 (Gen-Probe) | FVU, swab Swab | None | | PCR-MOMP | FVU | Positive: 2/3 or 3/3 positive assay results | 577 | Proportion not reported | STD clinic Utah | 18.7% | LCR (swab) | 0.96 | 1.00
Carroll et al^ 63 ^/1998 | LCR PACE 2 (Gen-Probe) | FVU, swab Swab | None | | PCR-MOMP | FVU | Positive: 2/3 or 3/3 positive assay results | 577 | Proportion not reported | STD clinic Utah | 18.7% | LCR (FVU) | 0.93 | 1.00
Buimer, 1996 | LCR | FVU, swab | Culture | swab | repeat LCR | FVU | Positive: +Culture or | 614.00 | A/S | STD clinic, Netherlands | 7.0% by Culture | Culture | . | | 1.00 | 0.94
Gun-Munro et al^ 118 ^/1996 | EIA (VIDAS) EIA (Chlamydiazyme) | FVU FVU | PCR | FVU | Blocked EIA and confirmed PCR | FVU | Positive: culture+ or confirmed PCR | 100 | Proportion not reported | Hospital-based STD clinic McMaster University, Canada | 14.0% | EIA (VIDAS-FVU) | 0.69 | 1.00 | 1.00 | 0.94
Gun-Munro et al^ 118 ^/1996 | EIA (VIDAS) EIA (Chlamydiazyme) | FVU FVU | PCR | FVU | Blocked EIA and confirmed PCR | FVU | Positive: culture+ or confirmed PCR | 100 | Proportion not reported | Hospital-based STD clinic McMaster University, Canada | 14.0% | EIA (Chlamydiazyme-FVU) | 0.88 | 1.00 | 1.00 | 0.98
Steingrimsson et al^ 111 ^/1994 | EIA (VIDAS) ELFA (VIDAS) EIA (Chlamydiazyme) | Swab, FVU Swab, FVU Swab, FVU | Culture | Swab | DFA | Swab, FVU | Positive: culture+ and EIA+ or DFA+ | 245 | Symptoms or contacts 71% asymptomatic | State STD clinic Reykjavik, Iceland Median age 23 (15-46) | 30.6% | Culture | 0.93 | 1.00 | 1.00 | 0.97
Steingrimsson et al^ 111 ^/1994 | EIA (VIDAS) ELFA (VIDAS) EIA (Chlamydiazyme) | Swab, FVU Swab, FVU Swab, FVU | Culture | Swab | DFA | Swab, FVU | Positive: culture+ and EIA+ or DFA+ | 245 | Symptoms or contacts 71% asymptomatic | State STD clinic Reykjavik, Iceland Median age 23 (15-46) | 30.6% | EIA (Chlamydiazyme-swab) | 0.76 | 0.99 | 0.97 | 0.90
Steingrimsson et al^ 111 ^/1994 | EIA (VIDAS) ELFA (VIDAS) EIA (Chlamydiazyme) | Swab, FVU Swab, FVU Swab, FVU | Culture | Swab | DFA | Swab, FVU | Positive: culture+ and EIA+ or DFA+ | 245 | Symptoms or contacts 71% asymptomatic | State STD clinic Reykjavik, Iceland Median age 23 (15-46) | 30.6% | EIA (Chlamydiazyme-FVU) | 0.65 | 1.00 | 1.00 | 0.84
Steingrimsson et al^ 111 ^/1994 | EIA (VIDAS) ELFA (VIDAS) EIA (Chlamydiazyme) | Swab, FVU Swab, FVU Swab, FVU | Culture | Swab | DFA | Swab, FVU | Positive: culture+ and EIA+ or DFA+ | 245 | Symptoms or contacts 71% asymptomatic | State STD clinic Reykjavik, Iceland Median age 23 (15-46) | 30.6% | EIA (VIDAS-swab) | 0.71 | 0.92 | 0.80 | 0.87
Steingrimsson et al^ 111 ^/1994 | EIA (VIDAS) ELFA (VIDAS) EIA (Chlamydiazyme) | Swab, FVU Swab, FVU Swab, FVU | Culture | Swab | DFA | Swab, FVU | Positive: culture+ and EIA+ or DFA+ | 245 | Symptoms or contacts 71% asymptomatic | State STD clinic Reykjavik, Iceland Median age 23 (15-46) | 30.6% | EIA (VIDAS-FVU) | 0.75 | 0.96 | 0.91 | 0.88
Talbot and Romanowski^ 119 ^/ 1994 | EIA (Microtrak) EIA (Chlamydiazyme) EIA (IEDIA) | FVU FVU FVU | Culture | Swab | DFA | FVU | Positive: culture+ or DFA + | 318 | Proportion not reported | STD clinic Edmonton, Canada | 14.8% | EIA (MicroTrak-FVU) | 0.78 | 1.00 | 0.97 | 0.97
Talbot and Romanowski^ 119 ^/ 1994 | EIA (Microtrak) EIA (Chlamydiazyme) EIA (IEDIA) | FVU FVU FVU | Culture | Swab | DFA | FVU | Positive: culture+ or DFA + | 318 | Proportion not reported | STD clinic Edmonton, Canada | 14.8% | EIA (Chlamydiazyme-FVU) | 0.76 | 1.00 | 1.00 | 0.96
Talbot and Romanowski^ 119 ^/ 1994 | EIA (Microtrak) EIA (Chlamydiazyme) EIA (IEDIA) | FVU FVU FVU | Culture | Swab | DFA | FVU | Positive: culture+ or DFA + | 318 | Proportion not reported | STD clinic Edmonton, Canada | 14.8% | EIA (IEDIA-FVU) | 0.81 | 0.98 | 0.85 | 0.97
Bygdeman et al^ 64 ^/1994 | EIA (Magic Lite) | FVU | Culture | Swab | DIF | FVU | Positive: culture+ or DIF+ | 557 | 28% symptomatic | STD clinic Sweden Mean age 28.2 (16-69) | 13.7% | EIA (swab) | 0.61 | 1.00 | 0.96 | 0.94
Bygdeman et al^ 64 ^/1994 | EIA (Magic Lite) | FVU | Culture | Swab | DIF | FVU | Positive: culture+ or DIF+ | 557 | 28% symptomatic | STD clinic Sweden Mean age 28.2 (16-69) | 13.7% | EIA (FVU) | 0.63 | 0.99 | 0.94 | 1.00
Moncada et al^ 120 ^/1994 | EIA (Chlamydiazyme) | FVU | Culture | Swab | DFA | FVU | Positive: culture+ or 2 antigen+ tests | 816 | All asymptomatic | U.S. military ship, university and high school students STD clinics San Francisco, Calif | 6% asymptomatic | EIA (Chlamydiazyme-FVU) | 0.77 | 0.97 | 0.64 | 0.98
Chernesky et al^ 121 ^/1995 | EIA (IMX Select) EIA (Chlamydiazyme) | FVU, swab FVU | Culture | Swab | DIF (MicroTrak) | | Positive: culture+ or 1 or more antigen+ tests | 203 | 73% symptomatic | STD clinic Ontario, Canada | 11.3% | EIA (IMX-swab) | 0.89 | 0.99 | 0.96 | 0.98
Chernesky et al^ 121 ^/1995 | EIA (IMX Select) EIA (Chlamydiazyme) | FVU, swab FVU | Culture | Swab | DIF (MicroTrak) | | Positive: culture+ or 1 or more antigen+ tests | 203 | 73% symptomatic | STD clinic Ontario, Canada | 11.3% | EIA (IMX-FVU) | 0.81 | 1.00 | 1.00 | 0.97
Chernesky et al^ 121 ^/1995 | EIA (IMX Select) EIA (Chlamydiazyme) | FVU, swab FVU | Culture | Swab | DIF (MicroTrak) | | Positive: culture+ or 1 or more antigen+ tests | 203 | 73% symptomatic | STD clinic Ontario, Canada | 11.3% | EIA (Chlamydiazine-FVU) | 0.73 | 1.00 | 1.00 | 0.96
Chernesky et al^ 121 ^/1995 | EIA (IMX Select) EIA (Chlamydiazyme) | FVU, swab FVU | Culture | Swab | DIF (MicroTrak) | | Positive: culture+ or 1 or more antigen+ tests | 203 | 73% symptomatic | STD clinic Ontario, Canada | 11.3% | Culture | 0.62 | 1.00 | 1.00 | 0.95
Sanders et al^ 122 ^/1994 | EIA (Baxter-Bartels) | FVU | Culture | Swab | DFA | FVU, swab | Positive: culture+ or 2 antigen+ tests | 1486 | 60% asymptomatic | 2 STD clinics Baltimore, Md African American 95% Heterosexuals 97% Mean age 27 | Asymptomatic 7.7% by culture, 8.9% by culture/DFA Symptomatic 10.9% by culture, 11.6% by culture/DFA | EIA (FVU) | 0.85 | 0.99 | 0.92 | 0.99
Sanders et al^ 122 ^/1994 | EIA (Baxter-Bartels) | FVU | Culture | Swab | DFA | FVU, swab | Positive: culture+ or 2 antigen+ tests | 1486 | 60% asymptomatic | 2 STD clinics Baltimore, Md African American 95% Heterosexuals 97% Mean age 27 | Asymptomatic 7.7% by culture, 8.9% by culture/DFA Symptomatic 10.9% by culture, 11.6% by culture/DFA | Culture | 0.87 | 1.00 | 1.00 | 0.99
Sanders et al^ 122 ^/1994 | EIA (Baxter-Bartels) | FVU | Culture | Swab | DFA | FVU, swab | Positive: culture+ or 2 antigen+ tests | 1486 | 60% asymptomatic | 2 STD clinics Baltimore, Md African American 95% Heterosexuals 97% Mean age 27 | Asymptomatic 7.7% by culture, 8.9% by culture/DFA Symptomatic 10.9% by culture, 11.6% by culture/DFA | LE test | 0.57 | 0.70 | 0.14 | 0.85
Domeika et al^ 123 ^/1994 | EIA (Orion) EIA (MicroTrak) DIF (MicroTrak) | FVU FVU FVU | None | | Culture | Swab | Positive: culture+ or 2 more more antigen+ tests | 749 | All asymptomatic | Military recruits (mean age 19.7) = 309 Adolescent students (mean age 18) = 246 STD clinics (mean age 29) = 194 | 0.4% to 58.6% depending on population | EIA (MicroTrak-FVU) | 0.99 | 1.00 | 0.99 | 1.00
Domeika et al^ 123 ^/1994 | EIA (Orion) EIA (MicroTrak) DIF (MicroTrak) | FVU FVU FVU | None | | Culture | Swab | Positive: culture+ or 2 more more antigen+ tests | 749 | All asymptomatic | Military recruits (mean age 19.7) = 309 Adolescent students (mean age 18) = 246 STD clinics (mean age 29) = 194 | 0.4% to 58.6% depending on population | EIA (Orion-FVU) | 0.74 | 1.00 | 1.00 | 0.95
Domeika et al^ 123 ^/1994 | EIA (Orion) EIA (MicroTrak) DIF (MicroTrak) | FVU FVU FVU | None | | Culture | Swab | Positive: culture+ or 2 more more antigen+ tests | 749 | All asymptomatic | Military recruits (mean age 19.7) = 309 Adolescent students (mean age 18) = 246 STD clinics (mean age 29) = 194 | 0.4% to 58.6% depending on population | DIF (MicroTrak-FVU) | 0.99 | 1.00 | 1.00 | 1.00
Gaydos et al^ 70 ^/1996 | LCR EIA (Syva) | FVU FVU | None | | LCR-MOMP | FVU | Positive: LCR+ or EIA+ and LCR-MOMP+ | 300 | 39% symptomatic | Public health clinic (57% ) STD clinic (43%) Malaysia | 10% after discrepant test | LCR (FVU) | 1.00 | 1.00 | 0.97 | 1.00
Gaydos et al^ 70 ^/1996 | LCR EIA (Syva) | FVU FVU | None | | LCR-MOMP | FVU | Positive: LCR+ or EIA+ and LCR-MOMP+ | 300 | 39% symptomatic | Public health clinic (57% ) STD clinic (43%) Malaysia | 10% after discrepant test | EIA (FVU) | 0.10 | 1.00
Buimer et al^ 71 ^/1996 | LCR | FVU, swab | Culture | Swab | Repeat LCR and LCR-MOMP | FVU, swab | Positive: culture+ or at least 1 LCR+ result | 614 | Proportion not reported | STD clinic Netherlands Mean age 36.8 (range 17-69) | 7.0% by culture | Culture | 0.57 | 1.00 | 1.00 | 0.94
Buimer et al^ 71 ^/1996 | LCR | FVU, swab | Culture | Swab | Repeat LCR and LCR-MOMP | FVU, swab | Positive: culture+ or at least 1 LCR+ result | 614 | Proportion not reported | STD clinic Netherlands Mean age 36.8 (range 17-69) | 11.4% by LCR (swab) | LCR (swab) | 0.93 | 1.00 | 1.00 | 0.99
Buimer et al^ 71 ^/1996 | LCR | FVU, swab | Culture | Swab | Repeat LCR and LCR-MOMP | FVU, swab | Positive: culture+ or at least 1 LCR+ result | 614 | Proportion not reported | STD clinic Netherlands Mean age 36.8 (range 17-69) | 9.9% by LCR (FVU) | LCR (FVU) | 0.77 | 0.99 | 0.95 | 0.97
van Doornum et al^ 53 ^/1995 | LCR | FVU | Culture | Swab | Repeat LCR and LCR-MOMP | FVU | Positive: culture+ or LCR+/LCR-MOMP+ | 163 258 | Proportion not reported | 2 populations from STD clinics Amsterdam | 12.7% after discrepant test | LCR (FVU) | 0.86 | 1.00 | 1.00 | 0.98
van Doornum et al^ 53 ^/1995 | LCR | FVU | Culture | Swab | Repeat LCR and LCR-MOMP | FVU | Positive: culture+ or LCR+/LCR-MOMP+ | 163 258 | Proportion not reported | 2 populations from STD clinics Amsterdam | 12.7% after discrepant test | Culture | 0.82 | 1.00 | 1.00 | 0.98
Stary et al^ 124 ^/1996 | LCR PCR EIA (Microtrak) | FVU FVU FVU | None | | Retested with all 3 tests, then DFA and LCR-MOMP | FVU | Positive: confirmed+ by DT | 705 | All asymptomatic | Military recruits Austria | 4.1% after discrepant test | LCR (FVU) | 0.93 | 1.00 | 1.00 | 1.00
Stary et al^ 124 ^/1996 | LCR PCR EIA (Microtrak) | FVU FVU FVU | None | | Retested with all 3 tests, then DFA and LCR-MOMP | FVU | Positive: confirmed+ by DT | 705 | All asymptomatic | Military recruits Austria | 4.1% after discrepant test | PCR (FVU) | 0.62 | 1.00 | 0.86 | 0.98
Stary et al^ 124 ^/1996 | LCR PCR EIA (Microtrak) | FVU FVU FVU | None | | Retested with all 3 tests, then DFA and LCR-MOMP | FVU | Positive: confirmed+ by DT | 705 | All asymptomatic | Military recruits Austria | 4.1% after discrepant test | EIA (FVU) | 0.38 | 0.98 | 0.46 | 0.97
Chernesky et al^ 125 ^/1994 | LCR EIA (Chlamydiazyme) | FVU FVU | Culture | Swab | DFA, LCR-MOMP | FVU | Positive: culture+ or DFA+/LCR-MOMP+ | 305 | Proportion not reported | STD clinic Ontario, Canada | 6.9% by culture | Culture | 0.38 | 1.00 | 1.00 | 0.88
Chernesky et al^ 125 ^/1994 | LCR EIA (Chlamydiazyme) | FVU FVU | Culture | Swab | DFA, LCR-MOMP | FVU | Positive: culture+ or DFA+/LCR-MOMP+ | 305 | Proportion not reported | STD clinic Ontario, Canada | 12.5% by EIA | EIA (FVU) | 0.68 | 1.00 | 1.00 | 0.93
Chernesky et al^ 125 ^/1994 | LCR EIA (Chlamydiazyme) | FVU FVU | Culture | Swab | DFA, LCR-MOMP | FVU | Positive: culture+ or DFA+/LCR-MOMP+ | 305 | Proportion not reported | STD clinic Ontario, Canada | 17.1% by LCR | LCR (FVU) | 0.96 | 1.00 | 1.00 | 0.99
Chernesky et al^ 72 ^/1994 | LCR | FVU, swab | Culture | Swab | DFA, LCR-MOMP | FVU | Positive: culture+ or LCR-MOMP+ or DFA+ | 542 (A) 1043 (B) | 129 asymptomatic (A) 451 asymptomatic (B) | STD clinics Baltimore, Md; Brooklyn, NY; and San Francisco, Calif (A) STD clinics Baltimore,Md; Hamilton, Ontario; Seattle, Wash (B) | 13.5% by culture (A) | Culture (A) | 0.72
Chernesky et al^ 72 ^/1994 | LCR | FVU, swab | Culture | Swab | DFA, LCR-MOMP | FVU | Positive: culture+ or LCR-MOMP+ or DFA+ | 542 (A) 1043 (B) | 129 asymptomatic (A) 451 asymptomatic (B) | STD clinics Baltimore, Md; Brooklyn, NY; and San Francisco, Calif (A) STD clinics Baltimore,Md; Hamilton, Ontario; Seattle, Wash (B) | 18.3% by LCR (A) | LCR (A) | 0.98
Chernesky et al^ 72 ^/1994 | LCR | FVU, swab | Culture | Swab | DFA, LCR-MOMP | FVU | Positive: culture+ or LCR-MOMP+ or DFA+ | 542 (A) 1043 (B) | 129 asymptomatic (A) 451 asymptomatic (B) | STD clinics Baltimore, Md; Brooklyn, NY; and San Francisco, Calif (A) STD clinics Baltimore,Md; Hamilton, Ontario; Seattle, Wash (B) | 8.3% by culture (B) | Culture (B) | 0.57 | 1.00 | 1.00 | 0.93
Chernesky et al^ 72 ^/1994 | LCR | FVU, swab | Culture | Swab | DFA, LCR-MOMP | FVU | Positive: culture+ or LCR-MOMP+ or DFA+ | 542 (A) 1043 (B) | 129 asymptomatic (A) 451 asymptomatic (B) | STD clinics Baltimore, Md; Brooklyn, NY; and San Francisco, Calif (A) STD clinics Baltimore,Md; Hamilton, Ontario; Seattle, Wash (B) | 14.0% by LCR (B) | LCR (B) | 0.94 | 1.00 | 0.99 | 0.99
Stary et al^ 73 ^/1998 | LCR TMA (Gen-Probe) | FVU, swab FVU, swab | Culture | Swab | DFA, TMA-rRNA | FVU, swab | Positive: culture+ or LCR+/TMA+/DFA+ or rRNA+ | 240 | Proportion not reported | STD center Austria | 18.3% | TMA (swab) | 0.93 | 0.99 | 0.95 | 0.99
Stary et al^ 73 ^/1998 | LCR TMA (Gen-Probe) | FVU, swab FVU, swab | Culture | Swab | DFA, TMA-rRNA | FVU, swab | Positive: culture+ or LCR+/TMA+/DFA+ or rRNA+ | 240 | Proportion not reported | STD center Austria | 18.3% | TMA (FVU) | 0.89 | 0.99 | 0.95 | 0.98
Stary et al^ 73 ^/1998 | LCR TMA (Gen-Probe) | FVU, swab FVU, swab | Culture | Swab | DFA, TMA-rRNA | FVU, swab | Positive: culture+ or LCR+/TMA+/DFA+ or rRNA+ | 240 | Proportion not reported | STD center Austria | 18.3% | LCR (swab) | 0.93 | 1.00 | 0.98 | 0.99
Stary et al^ 73 ^/1998 | LCR TMA (Gen-Probe) | FVU, swab FVU, swab | Culture | Swab | DFA, TMA-rRNA | FVU, swab | Positive: culture+ or LCR+/TMA+/DFA+ or rRNA+ | 240 | Proportion not reported | STD center Austria | 18.3% | LCR (FVU) | 0.86 | 1.00 | 0.97 | 0.97
Stary et al^ 73 ^/1998 | LCR TMA (Gen-Probe) | FVU, swab FVU, swab | Culture | Swab | DFA, TMA-rRNA | FVU, swab | Positive: culture+ or LCR+/TMA+/DFA+ or rRNA+ | 240 | Proportion not reported | STD center Austria | 18.3% | Culture | 0.50 | 1.00 | 1.00 | 0.90
Stary et al^ 112 ^/1996 | PCR (Amplicor) EIA (Microtrak) PACE 2 (Gen-Probe) | FVU, swab FVU, swab Swab | None | | PCR-MOMP DIF probe competition assay | FVU, swab | Positive: result+ confirmed by DT | 344 | 66% symptomatic | STD clinic Austria | 11.3% | PCR (swab) | 0.80 | 1.00 | 1.00 | 0.97
Stary et al^ 112 ^/1996 | PCR (Amplicor) EIA (Microtrak) PACE 2 (Gen-Probe) | FVU, swab FVU, swab Swab | None | | PCR-MOMP DIF probe competition assay | FVU, swab | Positive: result+ confirmed by DT | 344 | 66% symptomatic | STD clinic Austria | 11.3% | PCR (FVU) | 0.75 | 1.00 | 1.00 | 0.97
Stary et al^ 112 ^/1996 | PCR (Amplicor) EIA (Microtrak) PACE 2 (Gen-Probe) | FVU, swab FVU, swab Swab | None | | PCR-MOMP DIF probe competition assay | FVU, swab | Positive: result+ confirmed by DT | 344 | 66% symptomatic | STD clinic Austria | 11.3% | EIA (FVU) | 0.75 | 1.00 | 1.00 | 0.97
Stary et al^ 112 ^/1996 | PCR (Amplicor) EIA (Microtrak) PACE 2 (Gen-Probe) | FVU, swab FVU, swab Swab | None | | PCR-MOMP DIF probe competition assay | FVU, swab | Positive: result+ confirmed by DT | 344 | 66% symptomatic | STD clinic Austria | 11.3% | PACE 2 (swab) | 0.62 | 1.00 | 0.92 | 0.95
Mouton et al^ 78 ^/1997 | TMA (Gen-Probe) | FVU | Culture | Swab | PCR (in-house) | FVU | Positive: culture+/TMA+ or culture+/TMA-/PCR+ | 544 | Proportion not reported | STD outpatient clinic Rotterdam, Netherlands | 6.8% by culture | TMA (FVU) | 1.00 | 0.99 | 0.93 | 1.00
Mouton et al^ 78 ^/1997 | TMA (Gen-Probe) | FVU | Culture | Swab | PCR (in-house) | FVU | Positive: culture+/TMA+ or culture+/TMA-/PCR+ | 544 | Proportion not reported | STD outpatient clinic Rotterdam, Netherlands | 6.8% by culture | Culture | 0.57 | 0.99 | 0.86 | 0.95
Crotchfelt et al^ 79 ^/1998 | TMA (Gen-Probe) | FVU | Culture | Swab | DIF, TMA-16S rRNA | FVU, swab | Positive: culture+ or TMA- with DIF+ or TMA-16S rRNA+ | 464 | Proportion not reported | STD clinic and adolescent clinic Baltimore, Md; Brooklyn, NY; and San Francisco, Calif (A) | 6.0% | TMA (FVU) | 0.96 | 0.99 | 0.93 | 0.99
Crotchfelt et al^ 79 ^/1998 | TMA (Gen-Probe) | FVU | Culture | Swab | DIF, TMA-16S rRNA | FVU, swab | Positive: culture+ or TMA- with DIF+ or TMA-16S rRNA+ | 464 | Proportion not reported | STD clinic and adolescent clinic Baltimore, Md; Brooklyn, NY; and San Francisco, Calif (A) | 6.0% | Culture | 0.59 | 1.00 | 1.00 | 0.93

PCR, polymerase chain reaction; FVU, first void urine; MOMP, major outer membrane protein; DIF, direct immunofluorescence; STD, sexually transmitted disease; DB, radioimmune dot blot; A, Austria; V,Vienna; LCR, ligase chain reaction; PACE 2,a nucleic acid hybridization technique; VIDAS, IEDIA, IMX, different brands of test;TMA, transcription-medicated amplification;rRNA, ribosomal RNA.

Evidence Table 6. Overview of cost studies—screening in womenAppendix 1: Evidence Tables

Author/Year | Type of Study | Study Design | Setting/Population | Perspective | Comparisons | Primary Outcome | Cost Data Sources | Discount Rate | Reference Case Results | Sensitivity Analyses | Quality Score*
Marrazzo et al^ 139 ^/1997 | CEA | Cross sectional with decision analysis | Women undergoing pelvic exam in family planning and STD clinics NW United States (Region X) (3%-10% pregnant) 1989-1993 | Societal | No screening vs. selective vs. universal (with DFA or LCR) | Cases of chlamydia infection cured | Published studies | 5% | Selective screening is dominant in STD clinics; universal screening is dominant in FP clinics, costs $53/ infection prevented | Results sensitive to prevalence of risk factors and infection | 5/6
Howell et al^ 140 ^/1998 | CEA | Cross sectional with decision analysis | Women undergoing pelvic exam in family planning clinics Baltimore, MD (3% pregnant, 97% black)1994-1996 | Health care system (sensitivity analysis with indirect costs) | No screening vs. CDC criteria vs. women <30 vs. universal (with PCR) | Cases of PID prevented | Micro-costing, published studies | 3% | Screening all women <30 years of age is dominant; universal screening costs additional $3,000/case of PID prevented | Results sensitive to prevalence of risk factors and infection | 6/6
Humphreys et al^ 141 ^/1992 | CBA | Cross sectional with decision analysis | Women in family planning clinics Colorado 1998 | Not specified (direct costs only) | No screening vs. selective vs. universal | Dollars saved | Local hospital charges | Not specified | Universal screening is dominant | None | 2/6
Sellors et al^ 142 ^/1992 | CEA | Cross sectional with decision analysis | Women undergoing pelvic exam in family planning clinics Ontario 1989-1990 | Government | Universal vs. selective screening; culture vs. EIA vs. both | Cases of chlamydia detected | Local and provincial charges, published studies | 5% | Selective screening is dominant; universal screening costs additional $500 (Canadian)/case detected; EIA is dominant over culture | Sensitive to prevalence, test accuracy | 6/6
Genc and Mardh^ 143 ^/1996 | CEA | Decision analysis (hypothetical cohort) | Women undergoing pelvic exam in youth, Gyn, or family planning clinicsSweden | Not specified (societal) | No screening vs. culture vs. EIA vs. cervical DNA tests | Cases of chlamydia infection cured | National statistics | 5%-10% | Screening with cervical PCR/LCR is dominant | Results sensitive to prevalence, treatment compliance | 4/6
Howell et al^ 144 ^/1998 | CEA | Decision analysis (hypothetical cohort) | Women <30 years of age in family planning clinics Maryland (6% pregnant) 1994-1995 | Health care system | No screening vs. culture vs. EIA vs. urine and cervical DNA tests | Cases of PID prevented | Micro-costing, published studies | 3% | Screening with urine and cervical PCR and LCR is dominant | Results sensitive to percent of women undergoing pelvic exam | 6/6
Gift et al^ 145 ^/1999 | CEA | Decision analysis (hypothetical cohort) | Women undergoing pelvic exams in STD clinic | Health care system | Culture vs. PCR vs. EIA | Cases of PID prevented | Local charges, published studies | Not specified | Screening strategy of EIA with PCR for EIA-negative cases was dominant | Sensitive to follow-up rates, test accuracy, prevalence, costs of tests and downstream events | 4/6
Nettleman and Bell^ 146 ^/1991 | CEA | Decision analysis (hypothetical cohort) | Pregnant women United States | Not specified (sensitivity analysis with some indirect costs) | No screening vs. culture vs. direct antigen | Utility score: 0, untreated infection, 1, treated or no infection | Local charges, published studies | Not specified | Direct antigen test is more cost effective but increases costs compared with no screening | Results sensitive to prevalence, cost of tests, downstream and indirect costs | 4/6

*One point each for: (1) Stating perspective, (2) Describing benefits, (3) Specifying appropriate costs, (4) Discounting, (5) Sensitivity analysis, (6) Stating cost effectiveness or cost benefit ratio. (Adapted from Udvarhelyi et al.^23^).CEA, cost effectiveness analysis; CBA, cost benefit analysis; STD, sexually transmitted disease; DFA, direct fluorescent antibody; LCR, ligase chain reaction; PCR, polymerase chain reaction; PID, pelvic inflammatory disease;EIA, enzyme immunoassay